# References

1 King AC. Long-term home mechanical ventilation in the United States. Respir Care. 2012 Jun;57(6):921–30; discussion 30-2. doi: 10.4187/respcare.01741. PMID: 22663967.22663967
2 Bach JR, Intintola P, Alba AS, . The ventilator-assisted individual. Cost analysis of institutionalization vs rehabilitation and in-home management. Chest. 1992 Jan;101(1):26–30. PMID: 1729079.1729079
3 Marchese S, Lo Coco D, Lo Coco A. Outcome and attitudes toward home tracheostomy ventilation of consecutive patients: a 10-year experience. Respir Med. 2008 Mar;102(3):430–6. doi: 10.1016/j.rmed.2007.10.006. PMID: 18023334.18023334
4 MacIntyre NR, Epstein SK, Carson S, . Management of patients requiring prolonged mechanical ventilation: report of a NAMDRC consensus conference. Chest. 2005 Dec;128(6):3937–54. doi: 10.1378/chest.128.6.3937. PMID: 16354866.16354866
5 Simonds AK. Home Mechanical Ventilation: An Overview. Ann Am Thorac Soc. 2016 Nov;13(11):2035–44. doi: 10.1513/AnnalsATS.201606-454FR. PMID: 27560387.27560387
6 Guarascio AJ, Ray SM, Finch CK, . The clinical and economic burden of chronic obstructive pulmonary disease in the USA. Clinicoecon Outcomes Res. 2013;5:235–45. doi: 10.2147/ceor.s34321. PMID: 23818799.23818799
7 Murphy PB, Rehal S, Arbane G, . Effect of Home Noninvasive Ventilation With Oxygen Therapy vs Oxygen Therapy Alone on Hospital Readmission or Death After an Acute COPD Exacerbation: A Randomized Clinical Trial. JAMA. 2017 Jun 06;317(21):2177–86. doi: 10.1001/jama.2017.4451. PMID: 28528348.28528348
8 MacIntyre E, Asadi L, McKim DA, . Clinical outcomes associated with home mechanical ventilation: A systematic review. Can Respir J. 2015 Sep 30. PMID: 26422402.26422402
9 Lloyd-Owen SJ, Donaldson GC, Ambrosino N, . Patterns of home mechanical ventilation use in Europe: results from the Eurovent survey. Eur Respir J. 2005 Jun;25(6):1025–31. doi: 10.1183/09031936.05.00066704. PMID: 15929957.15929957
10 Miller RG, Jackson CE, Kasarskis EJ, . Practice parameter update: the care of the patient with amyotrophic lateral sclerosis: drug, nutritional, and respiratory therapies (an evidence-based review): report of the Quality Standards Subcommittee of the American Academy of Neurology. Neurology. 2009 Oct 13;73(15):1218–26. doi: 10.1212/WNL.0b013e3181bc0141. PMID: 19822872.19822872
11 McKim DA, Road J, Avendano M, . Home mechanical ventilation: a Canadian Thoracic Society clinical practice guideline. Can Respir J. 2011 Jul–Aug;18(4):197–215. PMID: 22059178.22059178
12 Windisch W, Walterspacher S, Siemon K, . Guidelines for non-invasive and invasive mechanical ventilation for treatment of chronic respiratory failure. Published by the German Society for Pneumology (DGP). Pneumologie. 2010 Oct;64(10):640–52. doi: 10.1055/s-0030-1255558. PMID: 20799159.20799159
13 Respiratory Network Domiciliary Non-Invasive Ventilation Working Group. Domiciliary non-invasive ventilation in adult patients-a consensus statement. NSW Agency for Clinical Innovation; 2012. https://www.aci.health.nsw.gov.au/__data/assets/pdf_file/0008/159794/ACI-NIV-guidelines.pdf. Accessed on August 28 2017.
14 Lewarski JS, Gay PC. Current issues in home mechanical ventilation. Chest. 2007 Aug;132(2):671–6. doi: 10.1378/chest.07-0558. PMID: 17699139.17699139
15 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD: Agency for Healthcare Research and Quality; January 2014. Chapters available at: www.effectivehealthcare.ahrq.gov.
16 Oscroft NS, Chadwick R, Davies MG, . Volume assured versus pressure preset non-invasive ventilation for compensated ventilatory failure in COPD. Respiratory Medicine. 2014 Oct;108(10):1508–15. doi: 10.1016/j.rmed.2014.07.010. PMID: 25123526.25123526
17 Paone G, Conti V, Biondi-Zoccai G, . Long-term home noninvasive mechanical ventilation increases systemic inflammatory response in chronic obstructive pulmonary disease: a prospective observational study. Mediators of Inflammation. 2014;2014:503145. doi: 10.1155/2014/503145. PMID: 24976687.24976687
18 Galli JA, Krahnke JS, James Mamary A, . Home non-invasive ventilation use following acute hypercapnic respiratory failure in COPD. Respiratory Medicine. 2014 May;108(5):722–8. doi: 10.1016/j.rmed.2014.03.006. PMID: 24702885.24702885
19 Bhatt SP, Peterson MW, Wilson JS, . Noninvasive positive pressure ventilation in subjects with stable COPD: a randomized trial. International Journal of Copd. 2013;8:581–9. doi: 10.2147/COPD.S53619. PMID: 24293994.24293994
20 Duiverman ML, Wempe JB, Bladder G, . Two-year home-based nocturnal noninvasive ventilation added to rehabilitation in chronic obstructive pulmonary disease patients: a randomized controlled trial. Respiratory Research. 2011 Aug 23;12:112. doi: 10.1186/1465-9921-12-112. PMID: 21861914.21861914
21 Duiverman ML, Wempe JB, Bladder G, . Nocturnal non-invasive ventilation in addition to rehabilitation in hypercapnic patients with COPD. Thorax. 2008 Dec;63(12):1052–7. PMID: 18710905.18710905
22 Oscroft NS, Quinnell TG, Shneerson JM, . Long-term non-invasive ventilation to manage persistent ventilatory failure after COPD exacerbation. Respirology. 2010 Jul;15(5):818–22. doi: 10.1111/j.1440-1843.2010.01787.x. PMID: 20546195.20546195
23 Cheung APS, Chan VL, Liong JT, . A pilot trial of non-invasive home ventilation after acidotic respiratory failure in chronic obstructive pulmonary disease. International Journal of Tuberculosis & Lung Disease. 2010 May;14(5):642–9. PMID: 20392360.20392360
24 Casanova C, Celli BR, Tost L, . Long-term controlled trial of nocturnal nasal positive pressure ventilation in patients with severe COPD. Chest. 2000 Dec;118(6):1582–90. PMID: 11115443.11115443
25 Garrod R, Mikelsons C, Paul EA, . Randomized controlled trial of domiciliary noninvasive positive pressure ventilation and physical training in severe chronic obstructive pulmonary disease. American Journal of Respiratory & Critical Care Medicine. 2000 Oct;162(4 Pt 1):1335–41. doi: 10.1164/ajrccm.162.4.9912029. PMID: 11029341.11029341
26 Clini E, Sturani C, Porta R, . Outcome of COPD patients performing nocturnal non-invasive mechanical ventilation. Respiratory Medicine. 1998 Oct;92(10):1215–22. PMID: 9926152.9926152
27 Clini E, Vitacca M, Foglio K, . Long-term home care programmes may reduce hospital admissions in COPD with chronic hypercapnia. European Respiratory Journal. 1996 Aug;9(8):1605–10. PMID: 8866580.8866580
28 Zhou L, Li X, Guan L, . Home noninvasive positive pressure ventilation with built-in software in stable hypercapnic COPD: A short-term prospective, multicenter, randomized, controlled trial. International Journal of COPD. 2017 27 Apr;12:1279–86. doi: 10.2147/COPD.S127540. PMID: 615975404.28490871
29 Marquez-Martin E, Ruiz FO, Ramos PC, . Randomized trial of non-invasive ventilation combined with exercise training in patients with chronic hypercapnic failure due to chronic obstructive pulmonary disease. Respiratory Medicine. 2014 Dec;108(12):1741–51. PMID: 25456710.25456710
30 Kohnlein T, Windisch W, Kohler D, . Non-invasive positive pressure ventilation for the treatment of severe stable chronic obstructive pulmonary disease: a prospective, multicentre, randomised, controlled clinical trial. The Lancet Respiratory Medicine. 2014 Sep;2(9):698–705. PMID: 25066329.25066329
31 De Backer L, Vos W, Dieriks B, . The effects of long-term noninvasive ventilation in hypercapnic COPD patients: a randomized controlled pilot study. International Journal of Copd. 2011;6:615–24. PMID: 22135493.22135493
32 Dreher M, Storre JH, Schmoor C, . High-intensity versus low-intensity non-invasive ventilation in patients with stable hypercapnic COPD: a randomised crossover trial. Thorax. 2010 Apr;65(4):303–8. PMID: 20388753.20388753
33 McEvoy RD, Pierce RJ, Hillman D, . Nocturnal non-invasive nasal ventilation in stable hypercapnic COPD: a randomised controlled trial. Thorax. 2009 Jul;64(7):561–6. PMID: 19213769.19213769
34 Tsolaki V, Pastaka C, Karetsi E, . One-year non-invasive ventilation in chronic hypercapnic COPD: effect on quality of life. Respiratory Medicine. 2008 Jun;102(6):904–11. PMID: 18280131.18280131
35 Windisch W, Dreher M, Storre JH, . Nocturnal non-invasive positive pressure ventilation: physiological effects on spontaneous breathing. Respiratory Physiology & Neurobiology. 2006 Feb 28;150(2–3):251–60. PMID: 15990366.15990366
36 Gay PC, Hubmayr RD, Stroetz RW. Efficacy of nocturnal nasal ventilation in stable, severe chronic obstructive pulmonary disease during a 3-month controlled trial. Mayo Clinic Proceedings. 1996 Jun;71(6):533–42. PMID: 8642881.8642881
37 Gad DM, El-Shafey AM. Non-invasive positive pressure ventilation and exercise training in patients with stable hypercapnic chronic obstructive pulmonary disease. Egyptian Journal of Chest Diseases and Tuberculosis. 2015 01 Jan;64(1):51–6. PMID: 601158661.
38 Sin DD, Wong E, Mayers I, . Effects of nocturnal noninvasive mechanical ventilation on heart rate variability of patients with advanced COPD. Chest. 2007 January;131(1):156–63. PMID: 46122988.17218570
39 Heinemann F, Budweiser S, Jörres RA, . The role of non-invasive home mechanical ventilation in patients with chronic obstructive pulmonary disease requiring prolonged weaning. Respirology. 2011;16(8):1273–80.21883681
40 Budweiser S, Hitzl A, Jörres R, . Impact of noninvasive home ventilation on long-term survival in chronic hypercapnic COPD: a prospective observational study. International journal of clinical practice. 2007;61(9):1516–22.17686094
41 Clini E, Sturani C, Rossi A, . The Italian multicentre study on noninvasive ventilation in chronic obstructive pulmonary disease patients. European Respiratory Journal. 2002;20(3):529–38.
42 Struik F, Sprooten R, Kerstjens H, . Nocturnal non-invasive ventilation in COPD patients with prolonged hypercapnia after ventilatory support for acute respiratory failure: a randomised, controlled, parallel-group study. Thorax. 2014:thoraxjnl-2014-205126.
43 Salturk C, Karakurt Z, Takir HB, . Comparison of exercise capacity in COPD and other etiologies of chronic respiratory failure requiring non-invasive mechanical ventilation at home: retrospective analysis of 1-year follow-up. International Journal of Copd. 2015;10:2559–69. doi: 10.2147/COPD.S91950. PMID: 26648713.26648713
44 Hitzl AP, Jorres RA, Heinemann F, . Nutritional status in patients with chronic respiratory failure receiving home mechanical ventilation: impact on survival. Clinical Nutrition. 2010 Feb;29(1):65–71. doi: 10.1016/j.clnu.2009.08.002. PMID: 19695747.19695747
45 Funk G-C, Breyer M-K, Burghuber OC, . Long-term non-invasive ventilation in COPD after acute-on-chronic respiratory failure. Respiratory Medicine. 2011 Mar;105(3):427–34. PMID: 21111590.21111590
46 Vasquez MM, McClure LA, Sherrill DL, . Positive Airway Pressure Therapies and Hospitalization in Chronic Obstructive Pulmonary Disease. American Journal of Medicine. 2017 Jul;130(7):809–18. doi: 10.1016/j.amjmed.2016.11.045. PMID: 28089799.28089799
47 Duiverman ML, Maagh P, Magnet FS, . Impact of High-Intensity-NIV on the heart in stable COPD: a randomised cross-over pilot study. Respiratory Research. 2017 05 02;18(1):76. PMID: 28464911.28464911
48 Blankenburg T, Benthin C, Pohl S, . Survival of hypercapnic patients with COPD and obesity hypoventilation syndrome treated with high intensity non invasive ventilation in the daily routine care. Open Respiratory Medicine Journal. 2017;11:31–40.
49 Durao V, Grafino M, Pamplona P. Chronic respiratory failure in patients with chronic obstructive pulmonary disease under home noninvasive ventilation: Real-life study. Pulmonology. 2018 Apr 05;05:05. PMID: 29628437.29628437
50 Oscroft NS, Quinnell TG, Shneerson JM, . The effects of withdrawing long-term nocturnal non-invasive ventilation in COPD patients. COPD: Journal of Chronic Obstructive Pulmonary Disease. 2010;7(2):111–6.20397811
51 Tsolaki V, Pastaka C, Kostikas K, . Noninvasive ventilation in chronic respiratory failure: effects on quality of life. Respiration. 2011;81(5):402–10.20588002
52 Windisch W, Walterspacher S, Siemon K, . Guidelines for non-invasive and invasive mechanical ventilation for treatment of chronic respiratory failure. Pneumologie. 2010;64(10):640–52.20799159
53 McKim DA, Road J, Avendano M, . Home mechanical ventilation: a Canadian Thoracic Society clinical practice guideline. Canadian Respiratory Journal. 2011 Jul–Aug;18(4):197–215. PMID: 22059178.22059178
54 Ambrosino N, Casaburi R, Chetta A, . 8<sup>th</sup> International conference on management and rehabilitation of chronic respiratory failure: The long summaries - Part 3. Multidisciplinary Respiratory Medicine. 2015 06 Oct;10 (1) (no pagination)(29). PMID: 606265044.
55 Porte P. Clinical indications for noninvasive positive pressure ventilation in chronic respiratory failure due to restrictive lung disease, COPD, and nocturnal hypoventilation - A consensus conference report. Chest. 1999;116(2):521–34. PMID: 29382139.10453883
56 National Guideline C. BTS/ICS guideline for the ventilatory management of acute hypercapnic respiratory failure in adults. 2016.
57 National Guideline C. VA/DoD clinical practice guideline for the management of chronic obstructive pulmonary disease. 2014.
58 National Institute for H, Clinical E. National Clinical Guideline Centre for Acute and Chronic Conditions. Chronic obstructive pulmonary disease. Management of chronic obstructive pulmonary disease in adults in primary and secondary care. National Institute for Health and Clinical Excellence. 2010.
59 Domenech-Clar R, Nauffal-Manzur D, Perpina-Tordera M, . Home mechanical ventilation for restrictive thoracic diseases: effects on patient quality-of-life and hospitalizations. Respiratory Medicine. 2003 Dec;97(12):1320–7. PMID: 14682414.14682414
60 Nauffal D, Domenech R, Martinez Garcia MA, . Noninvasive positive pressure home ventilation in restrictive disorders: outcome and impact on health-related quality of life. Respiratory Medicine. 2002 Oct;96(10):777–83. PMID: 12412976.12412976
61 Masa JF, Celli BR, Riesco JA, . The obesity hypoventilation syndrome can be treated with noninvasive mechanical ventilation. Chest. 2001;119(4):1102–7. doi: 10.1378/chest.119.4.1102. PMID: 32679437.11296176
62 Schonhofer B, Wallstein S, Wiese C, . Noninvasive mechanical ventilation improves endurance performance in patients with chronic respiratory failure due to thoracic restriction. Chest. 2001 May;119(5):1371–8. PMID: 11348941.11348941
63 Buyse B, Meersseman W, Demedts M. Treatment of chronic respiratory failure in kyphoscoliosis: oxygen or ventilation? European Respiratory Journal. 2003 Sep;22(3):525–8. PMID: 14516146.14516146
64 Hardinge M, Annandale J, Bourne S, . British Thoracic Society guidelines for Home Oxygen use in adults. Thorax. 2015 June;70:i1–i43. PMID: 608676290.25870317
65 Gonzalez-Bermejo J, Morelot-Panzini C, Arnol N, . Prognostic value of efficiently correcting nocturnal desaturations after one month of non-invasive ventilation in amyotrophic lateral sclerosis: A retrospective monocentre observational cohort study. Amyotrophic Lateral Sclerosis and Frontotemporal Degeneration. 2013 September;14(5–6):373–9. doi: 10.3109/21678421.2013.776086. PMID: 369532783.23527531
66 Sanjuan-Lopez P, Valino-Lopez P, Ricoy-Gabaldon J, . Amyotrophic lateral sclerosis: impact of pulmonary follow-up and mechanical ventilation on survival. A study of 114 cases. Archivos de Bronconeumologia. 2014 Dec;50(12):509–13. doi: 10.1016/j.arbres.2014.04.010. PMID: 24931271.24931271
67 Pinto AC, Evangelista T, Carvalho M, . Respiratory assistance with a non-invasive ventilator (Bipap) in MND/ALS patients: survival rates in a controlled trial. Journal of the Neurological Sciences. 1995 May;129 Suppl:19–26. PMID: 7595610.7595610
68 Sancho J, Servera E, Morelot-Panzini C, . Non-invasive ventilation effectiveness and the effect of ventilatory mode on survival in ALS patients. Amyotrophic Lateral sclerosis & Frontotemporal Degeneration. 2014 Mar;15(1–2):55–61. PMID: 24266679.24266679
69 Sivori M, Rodriguez GE, Pascansky D, . Outcome of sporadic amyotrophic lateral sclerosis treated with non-invasive ventilation and riluzole. Medicina. 2007;67(4):326–30. PMID: 17891927.17891927
70 Lo Coco D, Marchese S, Pesco MC, . Noninvasive positive-pressure ventilation in ALS: predictors of tolerance and survival. Neurology. 2006 Sep 12;67(5):761–5. PMID: 16899545.16899545
71 Bourke SC, Tomlinson M, Williams TL, . Effects of non-invasive ventilation on survival and quality of life in patients with amyotrophic lateral sclerosis: a randomised controlled trial. Lancet Neurology. 2006 Feb;5(2):140–7. PMID: 16426990.16426990
72 Pinto A, Almeida JP, Pinto S, . Home telemonitoring of non-invasive ventilation decreases healthcare utilisation in a prospective controlled trial of patients with amyotrophic lateral sclerosis. Journal of Neurology, Neurosurgery & Psychiatry. 2010 Nov;81(11):1238–42. doi: 10.1136/jnnp.2010.206680. PMID: 20826878.20826878
73 Sancho J, Martinez D, Bures E, . Bulbar impairment score and survival of stable amyotrophic lateral sclerosis patients after noninvasive ventilation initiation. Erj Open Research. 2018 Apr;4(2). PMID: 29670892.29670892
74 Vitacca M, Montini A, Lunetta C, . Impact of an early respiratory care programme with non-invasive ventilation adaptation in patients with amyotrophic lateral sclerosis. European Journal of Neurology. 2018 Mar;25(3):556–e33. PMID: 29266547.29266547
75 Bertella E, Banfi P, Paneroni M, . Early initiation of night-time NIV in an outpatient setting: A randomized non-inferiority study in ALS patients. European Journal of Physical and Rehabilitation Medicine. 2017;53(6):892–9.28382811
76 Aboussouan LS, Khan SU, Meeker DP, . Effect of noninvasive positive-pressure ventilation on survival in amyotrophic lateral sclerosis. Annals of internal medicine. 1997;127(6):450–3.9313002
77 Farrero E, Prats E, Povedano M, . Survival in amyotrophic lateral sclerosis with home mechanical ventilation: the impact of systematic respiratory assessment and bulbar involvement. Chest. 2005;127(6):2132–8.15947331
78 National Guideline C. Motor neurone disease: assessment and management. 2016.
79 National Guideline C. Practice parameter update: the care of the patient with amyotrophic lateral sclerosis: drug, nutritional, and respiratory therapies (an evidence-based review). Report of the Quality Standards Subcommittee of the American Academy of Neurology. 2009.
80 Finder JD, Birnkrant D, Carl J, . Respiratory care of the patient with Duchenne muscular dystrophy: ATS consensus statement. American journal of respiratory and critical care medicine. 2004;170(4):456.15302625
81 National Guideline C. EFNS guidelines on the clinical management of amyotrophic lateral sclerosis (MALS) &mdash; revised report of an EFNS task force. 2012.
82 Howard ME, Piper AJ, Stevens B, . A randomised controlled trial of CPAP versus non-invasive ventilation for initial treatment of obesity hypoventilation syndrome. Thorax. 2017 May;72(5):437–44. doi: 10.1136/thoraxjnl-2016-208559. PMID: 27852952.27852952
83 Ojeda Castillejo E, de Lucas Ramos P, López Martin S, . Noninvasive Mechanical Ventilation in Patients With Obesity Hypoventilation Syndrome. Long-term Outcome and Prognostic Factors. Archivos de Bronconeumologia. 2013. doi: 10.1016/j.arbr.2014.06.016.
84 Masa JF, Corral J, Alonso ML, . Efficacy of Different Treatment Alternatives for Obesity Hypoventilation Syndrome. Pickwick Study. American Journal of Respiratory & Critical Care Medicine. 2015 Jul 01;192(1):86–95. PMID: 25915102.25915102
85 Borel J-C, Tamisier R, Gonzalez-Bermejo J, . Noninvasive ventilation in mild obesity hypoventilation syndrome: a randomized controlled trial. Chest. 2012 Mar;141(3):692–702. PMID: 21885724.21885724
86 Murphy PB, Davidson C, Hind MD, . Volume targeted versus pressure support non-invasive ventilation in patients with super obesity and chronic respiratory failure: a randomised controlled trial. Thorax. 2012 Aug;67(8):727–34. PMID: 22382596.22382596
87 Piper AJ, Wang D, Yee BJ, . Randomised trial of CPAP vs bilevel support in the treatment of obesity hypoventilation syndrome without severe nocturnal desaturation. Thorax. 2008 May;63(5):395–401. PMID: 18203817.18203817
88 Priou P, Gagnadoux F, Tesse A, . Endothelial dysfunction and circulating microparticles from patients with obstructive sleep apnea. The American journal of pathology. 2010;177(2):974–83.20566740
89 Masa JF, Corral J, Caballero C, . Non-invasive ventilation in obesity hypoventilation syndrome without severe obstructive sleep apnoea. Thorax. 2016:thoraxjnl-2016-208501.
90 de Llano LAP, Golpe R, Piquer MO, . Short-term and long-term effects of nasal intermittent positive pressure ventilation in patients with obesity-hypoventilation syndrome. Chest. 2005;128(2):587–94.16100142
91 Corral J, Mogollon MV, Sanchez-Quiroga MA, . Echocardiographic changes with non-invasive ventilation and CPAP in obesity hypoventilation syndrome. Thorax. 2018 Apr;73(4):361–8. PMID: 29146865.29146865
92 Benhamou D, Muir JF, Raspaud C, . Long-term efficiency of home nasal mask ventilation in patients with diffuse bronchiectasis and severe chronic respiratory failure: a case-control study. Chest. 1997 Nov 05;112(5):1259–66. PMID: 9367466.9367466
93 Hazenberg A, Kerstjens HAM, Prins SCL, . Initiation of home mechanical ventilation at home: a randomised controlled trial of efficacy, feasibility and costs. Respiratory Medicine. 2014 Sep;108(9):1387–95. doi: 10.1016/j.rmed.2014.07.008. PMID: 25081652.25081652
94 Munoz X, Crespo A, Marti S, . Comparative study of two different modes of noninvasive home mechanical ventilation in chronic respiratory failure. Respiratory Medicine. 2006 Apr;100(4):673–81. doi: 10.1016/j.rmed.2005.08.008. PMID: 16194600.16194600
95 Chiang L-L, Liu C-Y, Ho S-C, . Efficacy of nocturnal nasal positive pressure ventilation in hypercapnic patients with severe obstructive lung diseases. Chang Gung Medical Journal. 2004 Feb;27(2):98–106. PMID: 15095954.15095954
96 Crespo A, Munoz X, Torres F, . Noninvasive home mechanical ventilation in elderly patients. Gerontology. 2010;56(2):150–6. doi: 10.1159/000237874. PMID: 19752508.19752508
97 Network AR. Domiciliary Non-Invasive Ventilation in Adult Patients: A Consensus Statement. 2012.
98 Moher D, Liberati A, Tetzlaff J, . Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. PLoS medicine. 2009;6(7):e1000097.19621072
99 Higgins JPT, Green S, eds. Cochrane handbook for systematic reviews of interventions Version 5.1.0 [updated March 2011]: The Cochrane Collaboration; 2011.
100 Wells G, Shea B, O’connell D, . The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. 2000.
101 Guyatt G, Rennie D, Meade M, . Users’ guides to the medical literature: McGraw-Hill Medical:; 2015.
102 Ioannidis JP, Trikalinos TA. The appropriateness of asymmetry tests for publication bias in meta-analyses: a large survey. CMAJ. 2007 Apr 10;176(8):1091–6. doi: 10.1503/cmaj.060410. PMID: 17420491.17420491
103 Davidson AC, Banham S, Elliott M, . BTS/ICS guideline for the ventilatory management of acute hypercapnic respiratory failure in adults. Thorax. 2016 Apr;71 Suppl 2:ii1–35. doi: 10.1136/thoraxjnl-2015-208209. PMID: 26976648.26976648
104 STATEMENTS Q. VA/DoD CLINICAL PRACTICE GUIDELINE FOR THE MANAGEMENT OF CHRONIC OBSTRUCTIVE PULMONARY DISEASE.
105 National Clinical Guideline C. National Institute for Health and Care Excellence: Clinical Guidelines. Motor Neurone Disease: Assessment and Management. London: National Institute for Health and Care Excellence (UK) Copyright (c) National Clinical Guideline Centre, 2016.; 2016.
106 Miller RG, Jackson CE, Kasarskis EJ, . Practice parameter update: the care of the patient with amyotrophic lateral sclerosis: drug, nutritional, and respiratory therapies (an evidence-based review): report of the Quality Standards Subcommittee of the American Academy of Neurology. Neurology. 2009 Oct 13;73(15):1218–26. doi: 10.1212/WNL.0b013e3181bc0141. PMID: 19822872.19822872
107 Andersen PM, Abrahams S, Borasio GD, . EFNS guidelines on the clinical management of amyotrophic lateral sclerosis (MALS)--revised report of an EFNS task force. Eur J Neurol. 2012 Mar;19(3):360–75. doi: 10.1111/j.1468-1331.2011.03501.x. PMID: 21914052.21914052