# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $5,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential non-financial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential non-financial conflicts of interest identified.

The list of Peer Reviewers follows:

- John Bach, MD
  Rutgers, New Jersey Medical School
  Newark, NJ
- Mark Helfand, MD, MPH
  Oregon Health & Sciences University
  Portland VA Medical Center
  Portland, OR
- Thomas J. Martin, MD
  Virginia Tech Carilion School of Medicine
  Edward Via Virginia College of Osteopathic Medicine
  Roanoke, VA
- Rahul Mukherjee, FRCP
  Heartlands Hospital
  Birmingham, United Kingdom