# [Noninvasive Positive Pressure Ventilation in the Home: Addendum]

## Justification

This is an addendum to the technology assessment report titled Noninvasive Positive Pressure Ventilation in the Home. This addendum is required to update the findings of the original report because of an updated literature search using the same search criteria (original report search was on June 26, 2018 and the updated search was on November 6, 2019) and some other minor changes due to a journal peer review and editorial process.

The updates in this amendment include updated results for Key Question 1 (Initiation Criteria for COPD), Key Question 2 (Device Effectiveness for COPD), and Key Question 3 (Device Effectiveness for COPD). The addendum included outcomes for NIPPV (BPAP and HMV combined) and post hoc subgroup analyses based on study design (RCTs vs. observational studies).

## Initiation Criteria for COPD (KQ1)

Two additional studies which described criteria for initiation of BPAP devices in patients with COPD were identified.^1,^ ^2^ The criteria used for initiation of BPAP are listed in Table 1. These criteria were generally similar to those in the original report.

Table 1 Updated results for initiation criteria for patients with COPD

Author, Year, Study Design | Device/mode | Patient characteristics to start or continue device | Laboratory characteristics to start or continue device | Device titration
Duiverman, 2019^1^ RCT | BPAP ST started in the hospital | - COPD (FEV1<50%); - Stable (no AECOPD in prior 4 weeks) | - PaCO2 >6.0 kPa (45 mmHg); - pH >7.35 (daytime, room air) | Settings adjusted to achieve normocapnia during the night or at least a reduction in nocturnal mean PtCo2 of 20% compared with the first night of spontaneous breathing. Initiation period ended once the patient could sleep 6 consecutive hours with the ventilator and the gas exchange goals were achieved.
Duiverman, 2019^1^ RCT | BPAP ST started in the home using telemedicine | - COPD (FEV1<50%); - Stable (no AECOPD in prior 4 weeks) | - PaCO2 >6.0 kPa (45 mmHg); - pH >7.35 (daytime, room air)
Satici, 2018^2^ Observational | BPAP S Treatment adherent (≥4 hours per day on ≥70% of days) | - COPD; - Prescribed home NIPPV for 6 months; - PaCO2 >55mmHg or PaCO2 50-55mmHg and nocturnal desaturation (<88% for at least 5 min) or; - 2 hospitalizations in 1 year | - PaCO2 >55mmHg or PaCO2 50-55mmHg and nocturnal desaturation (<88% for at least 5 min) or 2 hospitalizations in 1 year | NR
Satici, 2018^2^ Observational | BPAP S Treatment non-adherent | - COPD; - Prescribed home NIPPV for 6 months; - PaCO2 >55mmHg or PaCO2 50-55mmHg and nocturnal desaturation (<88% for at least 5 min) or; - 2 hospitalizations in 1 year | - PaCO2 >55mmHg or PaCO2 50-55mmHg and nocturnal desaturation (<88% for at least 5 min) or 2 hospitalizations in 1 year | NR

BPAP: Bilevel Positive Airway Pressure, COPD: chronic obstructive pulmonary disease, ST: spontaneous/timed breath mode, S: spontaneous mode, AECOPD: acute exacerbation of chronic obstructive pulmonary disease, FEV1: Forced expiratory volume in one second, kPa: kilopascal, mmHg: millimeters of mercury (pressure), NIPPV: Noninvasive positive pressure Ventilation, PaO2: partial pressure of arterial oxygen, PaCO2: partial pressure of arterial carbon dioxide, pH: potential of hydrogen, PtCO2: pressure of transcutaneous carbon dioxide

Risk of bias ratings for the two additional studies are listed in Tables 3 and 4.

Table 3 Updated risk of bias for randomized controlled trials (Cochrane ROB tool)

Author, Year | Sequence Generation | Allocation Concealment | Blinding of Participants Personnel | Blinding of Outcome Assessors | Incomplete Outcome Data | Selective Outcome Reporting | Other Sources of Bias | Overall RoB
Duiverman, 2019^1^ | Unclear | Unclear | High ROB | High ROB | High ROB | Low ROB | Low ROB | High ROB

ROB: Risk of Bias

Table 4 Updated risk of bias for observational studies (Newcastle-Ottawa Quality Assessment Scale)

Author, Year | Representativeness of the Study Population | Ascertainment of Exposure | Assessment of Outcome | Adequate Followup | Conflict of Interest | Overall RoB
Satici, 2018^2^ | High ROB | Low ROB | Low ROB | Low ROB | Low ROB | Moderate ROB

ROB: Risk of Bias

## Device Effectiveness for COPD (KQ2)

For NIPPV (combined BPAP or HMV), the major effectiveness outcomes (mortality, need for intubation, quality of life, hospital admission) are listed in Table 5.

Table 5 Major effectiveness outcomes with SOE (NIPPV vs. no device in COPD patients)

Outcome | Conclusion | Overall Evidence Strength (Direction of Effect)
Mortality | OR^*^: 0.65; 95% CI: 0.48 to 0.88 | Moderate (reduction with NIPPV)
Need for intubation | OR^*^: 0.34; 95% CI: 0.14 to 0.83 | Moderate (reduction with NIPPV)
Quality of life (higher score represents better outcome) | SMD^*^: 0.16, 95% CI: −0.06 to 0.32 | Insufficient
Number of hospital admissions | Rate Ratio^*^: 0.75; 95% CI: 0.52 to 1.10 | Low (no change with NIPPV)

NIPPV: noninvasive positive pressure ventilation; SOE: strength of evidence; COPD: chronic obstructive pulmonary disease; OR: odds ratio; SMD: standardized mean difference.

* Pooled effect size from meta-analysis

The results of the post hoc subgroup analyses for study design (RCTs vs. observational studies) are found in Table 6.

Table 6 Post-hoc subgroup analyses of study design on primary outcomes (NIPPV compared with no device)

Outcome | Study Design | Findings (95% CI) | I^2^
Mortality | 8 RCTs (985 patients)^3,4,5,6,7,^ ^8,9,10,11^ | OR=0.72 (0.49 to 1.05) | 26.9%
Mortality | 7 Observational studies (613 patients)^12,13,14,15,16,17,18^ | OR=0.58 (0.35 to 0.96) | 31.9%
Need for Intubation | 1 RCT (52 patients)^5^ | OR=0.48 (0.04 to 5.64) | N/A
Need for Intubation | 2 Observational studies (215 patients)^15,18^ | OR=0.32 (0.12 to 0.83) | 0.0%
Number of all-cause hospital admissions | 3 RCTs (243 patients)^5,6,10^ | Rate ratio=0.92 (0.67 to 1.26) | 35.3%
Number of all-cause hospital admissions | 3 Observational studies (176 patients)^14,17,18^ | Rate ratio=0.65 (0.40 to 1.06) | 53.0%
Quality of life (higher score represents worse outcome) | 6 RCTs (467 patients)^7,^ ^8,19,9,20,21,11^ | SMD=0.15 (−0.12 to 0.42) | 56.5%
Quality of life (higher score represents worse outcome) | 1 Observational study (49 patients)^18^ | SMD=0.97 (0.36 to 1.58) | N/A

NIPPV: noninvasive positive pressure ventilation; RD: risk difference; OR: odds ratio; SMD: standardized mean difference; RCT: randomized clinical trial

Effectiveness outcomes for the two additional studies which were identified are found in Table 7.

Table 7 Updated effectiveness outcomes in patients with COPD who used home NIPPV (compared with other NIPPV devices or device settings)

Comparison | Outcome | Study Design | Findings | Overall Evidence Strength (Direction of Effect)
BPAP S Treatment adherent (≥4 hours per day on ≥70% of days) vs. BPAP S Treatment non-adherent | Number of all-cause hospital admissions | 1 Observational study,^2^ 54 patients | 0.4 vs. 1.0 (p<0.01) | Low (reduction with BPAP S Treatment adherent)
BPAP S Treatment adherent (≥4 hours per day on ≥70% of days) vs. BPAP S Treatment non-adherent | Number of ICU admissions | 1 Observational study,^2^ 54 patients | 0.6 vs. 1.2 (p=0.37) | N/A
BPAP ST started in the home using telemedicine vs. BPAP ST started in the hospital | Mortality | 1 RCT,^1^ 67 patients | 6.06% vs. 2.94%; RD: 0.03, 95% CI:−0.07 to 0.13; OR: 2.13; 95% CI: 0.18 to 24.67; I^2^=N/A | Insufficient
BPAP ST started in the home using telemedicine vs. BPAP ST started in the hospital | Quality of life (Severe Respiratory Insufficiency Questionnaire Summary Score, higher score represents better outcome) | 1 RCT,^1^ 67 patients | WMD: −1.20; 95% CI: −9.92 to 7.52; I^2^=N/A | Insufficient
BPAP ST started in the home using telemedicine vs. BPAP ST started in the hospital | Dyspnea (Medical research council scale, higher score represents worse outcome) | 1 RCT,^1^ 67 patients | WMD: 0.10; 95% CI: −0.50 to 0.70; I^2^=N/A | N/A
BPAP ST started in the home using telemedicine vs. BPAP ST started in the hospital | 6-minute walk distance test (meters) | 1 RC,^1^ 67 patients | WMD: −19.00; 95% CI: −64.60 to 29.60; I^2^=N/A | N/A
BPAP ST started in the home using telemedicine vs. BPAP ST started in the hospital | Number of all-cause hospital admissions | 1 RCT,^1^ 67 patients | WMD: −0.10; 95% CI: −0.60 to 0.40; I^2^=N/A | Insufficient
BPAP ST started in the home using telemedicine vs. BPAP ST started in the hospital | Number of exacerbations | 1 RCT,^1^ 67 patients | No significant difference between the two groups | N/A

AECOPD: acute exacerbation of chronic obstructive pulmonary disease, BPAP: bi-level positive airway pressure, CI: confidence interval, COPD: chronic obstructive pulmonary disease, CPAP: continuous positive airway pressure, HMV: home mechanical ventilation, N/A: not applicable, NOS: not otherwise specified, OR: odds ratio, RCT: randomized controlled trial, RD: risk difference; ST: spontaneous/timed mode, WMD: weighted mean difference

In addition, the following changes were made: In patients with COPD, BPAP compared with no device was associated with fewer patients with hospital admissions but no difference in the total number of hospital admissions (Rate Ratio=0.91, 95% CI: 0.71 to 1.17) and quality of life (SMD=0.16, 95% CI: −0.03 to 0.39). In patients with stable COPD, NIPPV compared with no device was associated with no difference in the total number of hospital admissions (Rate Ratio=0.84, 95% CI: 0.59 to 1.18). In patients with COPD and recent exacerbation, NIPPV compared with no device was associated with no difference in mortality (OR=0.66, 95% CI: 0.41 to 1.06), but was associated with fewer hospital admissions (RR=0.59, 95% CI: 0.43 to 0.81).

NIPPV may be associated with improved quality of life in patients with higher PaCO2 compared with patients with lower PaCO2 (PaCO2≥ 52 mmHg: SMD=0.18; 95% CI: −0.05 to 0.40 vs. PaCO2 ≥50 to 51: SMD=0.97; 95% CI: 0.36 to 1.58 vs. PaCO2 ≥45 to 49: SMD= −0.06; 95% CI: −0.28 to 0.17).

## Device Characteristics for COPD (KQ3)

Two additional studies which described device characteristics for patients with COPD were identified.^1,^ ^2^ The device characteristics are listed in Table 8. These device characteristics were generally similar to those in the original report.

Table 8 Updated equipment parameters for patients with COPD

Author, Year, Study Design | Device/mode | Model (Manufacturer; Location of Manufacturer) | Device Characteristics | Prescribed Usage (frequency and duration) | Actual Usage
Duiverman, 2019^1^ RCT | BPAP ST started in the hospital | [underlined: BPAP]; BiPAP A30; Philips Respironics (FDA approved 510(k) clearance); BiPAP A40; Philips Respironics (FDA approved 510(k) clearance) | IPAP, EPAP, rate | NR | - 7.5 ± 2.0 hours/day; - IPAP: 25.7 ± 3.4 cm H2O; - EPAP: 6.0 ± 1.3 cm H2O; - Rate: 15.4 ± 3.0 breaths/minute
Duiverman, 2019^1^ RCT | BPAP ST started in the home using telemedicine | [underlined: BPAP]; BiPAP A30; Philips Respironics (FDA approved 510(k) clearance); BiPAP A40; Philips Respironics (FDA approved 510(k) clearance) | IPAP, EPAP, rate | NR | - 8.2 ± 1.7 hours/day; - IPAP: 23.6 ± 2.3 cm H2O; - EPAP: 4.6 ± 0.9 cm H2O; - Rate: 13.9 ± 2.0 breaths/minute
Satici, 2018^2^ Observational | BPAP S Treatment adherent (≥4 hours per day on ≥70% of days) | NR | IPAP, EPAP | NR | - 8.3± 4.0 hours/day; - IPAP: 22.3 ± 3.9 cm H2O; - EPAP: 8.3 ± 1.5 cm H2O
Satici, 2018^2^ Observational | BPAP S Treatment non-adherent | NR | IPAP, EPAP | NR | - 2.1± 2.0 hours/day; - IPAP: 20.9 ± 3.5 cm H2O; - EPAP: 7.7 ± 1.6 cm H2O

COPD: chronic obstructive pulmonary disease; RCT: randomized controlled trial; BPAP: Bilevel Positive Airway Pressure; S: spontaneous mode; ST: spontaneous/timed mode; cmH2O: centimeters of water (pressure); NR not reported; IPAP: inspiratory positive airway pressure; EPAP: expiratory positive airway pressure.

## References

1 Duiverman ML, Vonk JM, Bladder G, . Home initiation of chronic non-invasive ventilation in COPD patients with chronic hypercapnic respiratory failure: a randomised controlled trial. Thorax. 2019 Sep 4. doi: 10.1136/thoraxjnl-2019-213303. PMID: 31484786.31484786
2 Satici C, Arpinar Yigitbas B, Seker B, . Does Adherence to Domiciliary NIMV Decrease the Subsequent Hospitalizations Rates and Cost for Patients Diagnosed with COPD? Copd. 2018 Jun;15(3):303–9. doi: 10.1080/15412555.2018.1500532. PMID: 30188219.30188219
3 Murphy PB, Rehal S, Arbane G, . Effect of Home Noninvasive Ventilation With Oxygen Therapy vs Oxygen Therapy Alone on Hospital Readmission or Death After an Acute COPD Exacerbation: A Randomized Clinical Trial. Jama. 2017 06 06;317(21):2177–86. doi: 10.1001/jama.2017.4451. PMID: 28528348.28528348
4 Struik F, Sprooten R, Kerstjens H, . Nocturnal non-invasive ventilation in COPD patients with prolonged hypercapnia after ventilatory support for acute respiratory failure: a randomised, controlled, parallel-group study. Thorax. 2014:thoraxjnl-2014-205126.
5 Casanova C, Celli BR, Tost L, . Long-term controlled trial of nocturnal nasal positive pressure ventilation in patients with severe COPD. Chest. 2000 Dec;118(6):1582–90. PMID: 11115443.11115443
6 Clini E, Sturani C, Rossi A, . The Italian multicentre study on noninvasive ventilation in chronic obstructive pulmonary disease patients. European Respiratory Journal. 2002;20(3):529–38.
7 Duiverman ML, Wempe JB, Bladder G, . Two-year home-based nocturnal noninvasive ventilation added to rehabilitation in chronic obstructive pulmonary disease patients: a randomized controlled trial. Respir Res. 2011 Aug 23;12:112. doi: 10.1186/1465-9921-12-112. PMID: 21861914.21861914
8 Duiverman ML, Wempe JB, Bladder G, . Nocturnal non-invasive ventilation in addition to rehabilitation in hypercapnic patients with COPD. Thorax. 2008 Dec;63(12):1052–7. PMID: 18710905.18710905
9 Kohnlein T, Windisch W, Kohler D, . Non-invasive positive pressure ventilation for the treatment of severe stable chronic obstructive pulmonary disease: a prospective, multicentre, randomised, controlled clinical trial. Lancet Respir Med. 2014 Sep;2(9):698–705. PMID: 25066329.25066329
10 McEvoy RD, Pierce RJ, Hillman D, . Nocturnal non-invasive nasal ventilation in stable hypercapnic COPD: a randomised controlled trial. Thorax. 2009 Jul;64(7):561–6. PMID: 19213769.19213769
11 Zhou L, Li X, Guan L, . Home noninvasive positive pressure ventilation with built-in software in stable hypercapnic COPD: A short-term prospective, multicenter, randomized, controlled trial. International Journal of COPD. 2017 27 Apr;12:1279–86. doi: 10.2147/COPD.S127540. PMID: 615975404.28490871
12 Budweiser S, Hitzl A, Jörres R, . Impact of noninvasive home ventilation on long-term survival in chronic hypercapnic COPD: a prospective observational study. International journal of clinical practice. 2007;61(9):1516–22.17686094
13 Clini E, Sturani C, Porta R, . Outcome of COPD patients performing nocturnal non-invasive mechanical ventilation. Respiratory medicine. 1998 Oct;92(10):1215–22. PMID: 9926152.9926152
14 Clini E, Vitacca M, Foglio K, . Long-term home care programmes may reduce hospital admissions in COPD with chronic hypercapnia. European Respiratory Journal. 1996 Aug;9(8):1605–10. PMID: 8866580.8866580
15 Galli JA, Krahnke JS, James Mamary A, . Home non-invasive ventilation use following acute hypercapnic respiratory failure in COPD. Respiratory medicine. 2014 May;108(5):722–8. doi: 10.1016/j.rmed.2014.03.006. PMID: 24702885.24702885
16 Heinemann F, Budweiser S, Jörres RA, . The role of non-invasive home mechanical ventilation in patients with chronic obstructive pulmonary disease requiring prolonged weaning. Respirology. 2011;16(8):1273–80.21883681
17 Paone G, Conti V, Biondi-Zoccai G, . Long-term home noninvasive mechanical ventilation increases systemic inflammatory response in chronic obstructive pulmonary disease: a prospective observational study. Mediators Inflamm. 2014;2014:503145. doi: 10.1155/2014/503145. PMID: 24976687.24976687
18 Tsolaki V, Pastaka C, Karetsi E, . One-year non-invasive ventilation in chronic hypercapnic COPD: effect on quality of life. Respiratory medicine. 2008 Jun;102(6):904–11. PMID: 18280131.18280131
19 Garrod R, Mikelsons C, Paul EA, . Randomized controlled trial of domiciliary noninvasive positive pressure ventilation and physical training in severe chronic obstructive pulmonary disease. Am J Respir Crit Care Med. 2000 Oct;162(4 Pt 1):1335–41. doi: 10.1164/ajrccm.162.4.9912029. PMID: 11029341.11029341
20 Marquez-Martin E, Ruiz FO, Ramos PC, . Randomized trial of non-invasive ventilation combined with exercise training in patients with chronic hypercapnic failure due to chronic obstructive pulmonary disease. Respiratory medicine. 2014 Dec;108(12):1741–51. PMID: 25456710.25456710
21 Oscroft NS, Quinnell TG, Shneerson JM, . The effects of withdrawing long-term nocturnal non-invasive ventilation in COPD patients. COPD: Journal of Chronic Obstructive Pulmonary Disease. 2010;7(2):111–6.20397811