# Appendix H Figures

Figure H.1 6 Minute Walk Test-BPAP versus No Device in COPD patients

CI: Confidence interval; RCT: Randomized controlled trial; WMD: Weighted mean difference

This figure is a forest plot comparing BPAP to no device in COPD patients. The pooled effect from 7 studies shows patients treated by BPAP was not significantly different from patients not treated by any device on 6 minute walk test.

Figure H.2 Activities of Daily Living-BPAP versus No Device in COPD patients

CI: Confidence interval; RCT: Randomized controlled trial; SMD: Standardized mean difference

This figure is a forest plot comparing BPAP to no device in COPD patients. The pooled effect from 3 studies shows patients treated by BPAP was not significantly different from patients not treated by any device on activities of daily living.

Figure H.3 Dyspnea-BPAP versus No Device in COPD patients

CI: Confidence interval; RCT: Randomized controlled trial; SMD: Standardized mean difference

This figure is a forest plot comparing BPAP to no device in COPD patients. The pooled effect from 6 studies shows patients treated by BPAP had significantly better dyspnea scales than patients not treated by any device.

Figure H.4 Exacerbation-BPAP versus No Device in COPD patients

CI: Confidence interval; RCT: Randomized controlled trial

This figure is a forest plot comparing BPAP to no device in COPD patients. The pooled effect from 4 studies shows patients treated by BPAP was not significantly different from patients not treated by any device on COPD exacerbations.

Figure H.5 ICU admissions-BPAP versus No Device in COPD patients

CI: Confidence interval; RCT: Randomized controlled trial

This figure is a forest plot comparing BPAP to no device in COPD patients. The pooled effect from 2 studies shows patients treated by BPAP was not significantly different from patients not treated by any device on ICU admissions.

Figure H.6 Need for Intubation-BPAP versus No Device in COPD patients

CI: Confidence interval; OR: Odds Ratio RCT: Randomized controlled trial

This figure is a forest plot comparing BPAP to no device in COPD patients. The pooled effect from 3 studies shows patients treated by BPAP had significantly lower numbers of intubations than patients not treated by any device.

Figure H.7 Mortality-BPAP versus No Device in COPD patients

CI: Confidence interval; OR: Odds Ratio RCT: Randomized controlled trial

This figure is a forest plot comparing BPAP to no device in COPD patients. The pooled effect from 13 studies shows patients treated by BPAP had significantly lower mortality rate than patients not treated by any device.

Figure H.8 Quality of Life-BPAP versus No Device in COPD patients

CI: Confidence interval; RCT: Randomized controlled trial; SMD: Standardized mean difference

This figure is a forest plot comparing BPAP to no device in COPD patients. The pooled effect from 9 studies shows patients treated by BPAP were not significantly different from patients not treated by any device on quality of life scales.

Figure H.9 Hospital Readmission-BPAP versus No Device in COPD patients

CI: Confidence interval; RCT: Randomized controlled trial

This figure is a forest plot comparing BPAP to no device in COPD patients. The pooled effect from5 studies shows patients treated by BPAP were not significantly different from patients not treated by any device on hospital readmissions.

Figure H.10 Sleep Quality-BPAP versus No Device in COPD patients

CI: Confidence interval; RCT: Randomized controlled trial; SMD: Standardized mean difference

This figure is a forest plot comparing BPAP to no device in COPD patients. The pooled effect from 2 studies shows patients treated by BPAP were not significantly different from patients not treated by any device on sleep quality.

Figure H.11 Subgroup Analysis: Level of Hypercapnia (PaCO2) used as an Initiation Criterion for Initiation of NIPPV on Mortality-BPAP

CI: Confidence interval; OR: Odds Ratio RCT: Randomized controlled trial

This figure is a forest plot showing subgroup analyses of different levels of hypercapnia (PaCO2) used as an initiation criterion for initiation of NIPPV on mortality. When comparing BPAP use to no device use, higher PaCO2 levels (e.g. PaCO2 ≥52 mmHg compared to PaCO2 ≥50 compared to PaCO2 ≥45) were associated with non-statistically significant trends in reduced mortality.

Figure H.12 Subgroup Analysis: Level of Hypercapnia (PaCO2) used as an Initiation Criterion for Initiation of NIPPV on Hospital Readmission-BPAP versus No Device in COPD patients

CI: Confidence interval; OR: Odds Ratio RCT: Randomized controlled trial

This figure is a forest plot showing subgroup analyses of different levels of hypercapnia (PaCO2) used as an initiation criterion for initiation of NIPPV on hospital readmission. When comparing BPAP use to no device use, higher PaCO2 levels (e.g. PaCO2 ≥52 mmHg compared to PaCO2 ≥50 compared to PaCO2 ≥45) were associated with non-statistically significant trends in reduced hospital readmissions.

Figure H.13 Subgroup Analysis: Level of Hypercapnia (PaCO2) used as an Initiation Criterion for Initiation of NIPPV on Quality of Life-BPAP versus No Device in COPD Patients

CI: Confidence interval; RCT: Randomized controlled trial; SMD: Standardized mean difference

This figure is a forest plot showing subgroup analyses of different levels of hypercapnia (PaCO2) used as an initiation criterion for initiation of NIPPV on quality of life. When comparing BPAP use to no device use, higher PaCO2 levels (e.g. PaCO2 ≥52 mmHg compared to PaCO2 ≥50 compared to PaCO2 ≥45) were associated with statistically significant improvement on quality of life.