# Appendix D Characteristics of Included Studies

Table D.1 Characteristics of included studies