# Appendix A Flow Chart

Figure A.1 Flow chart

The figure shows the flow of the literature search and screening process. We identified 6,097 potential citations from database search and 63 from grey literature, reference mining, and Stakeholders/Key Informants. We removed 5,092 citations after title and abstract screening. In addition, 972 citations were removed after full-text screening. We also found 8 ongoing clinical trials and 12 systematic reviews. At the end, 61 original studies and 13 clinical guidelines met eligibility criteria and were included in the analyses.