# Management of CSF Leaks After Elective Spine Surgery: Routine Laminectomy Leads to Fatal Discitis and Sepsis

## Learning Objectives

At the conclusion of this case, participants should be able to:

- Identify the clinical manifestations of a cerebrospinal fluid (CSF) leak.
- Describe the workup to diagnose a CSF leak.
- List conservative and non-conservative measures to manage a CSF leak to prevent serious complications.

## The Case

A 70-year-old man underwent a L4-5 decompressive lumbar laminectomy and discectomy. The surgery was complicated by an intraoperative durotomy. Immediately after the operation, the surgeon informed the patient and instructed him to lie flat on his back for several days. The patient was subsequently discharged home. On postoperative day (POD) 6, the patient reported clear drainage from the surgical site. He was advised to continue to lie flat on his back until the drainage stopped. By POD 12, the patient noted ongoing clear fluid drainage, now accompanied by positional headaches. After re-evaluation by the spine surgical team, he was instructed to continue lying flat and to return the following day for further assessment. At the follow-up visit, the surgeon suspected a cerebrospinal fluid (CSF) leak based on examination. Bed rest was extended for another 5 days. However, drainage persisted, prompting further observation and a course of oral antibiotics.

On POD 22, at a subsequent clinic follow-up, the patient reported intermittent chills, continued drainage, and pain at the surgical site. Examination by the surgical team revealed a wound defect with “scant white/yellow liquid.” Wound care was initiated with home health nurses performing wet-to-dry dressing changes. Peroxide-soaked sterile cotton was applied to the drainage site after manual expression of discharge. On POD 25, the wound appeared to have dehisced, and the patient was readmitted to the hospital for advanced wound care and intravenous antibiotics. On POD 29, the wound was explored but no dural defect was found. Intraoperative cultures were negative for bacteria. The patient was discharged, but his condition worsened over the following week, with increasing back pain. On POD 42, the patient was readmitted and diagnosed after magnetic resonance imaging (MRI) with discitis and osteomyelitis. He was diagnosed with sepsis, which did not respond to escalating antibiotic treatment. On POD 50, he died after an episode of aspiration and cardiopulmonary arrest.

## The Commentary

By Jose A Castillo Jr, MD, Richard Price, MD, PhD, Kee D Kim, MD

### Introduction

Cerebrospinal fluid (CSF) leaks are a serious complication that can arise from injury to the dura, which is a thick fibrous membrane surrounding the brain and spinal cord. Most CSF leaks are iatrogenic, due to a dural tear during spinal surgery or anesthesia. With advances in surgical technology, spine surgeons have several options to manage intraoperative durotomies. CSF leaks also have varying degrees of severity. When the extravasated CSF forms a fibrous capsule beneath the skin, it is classified as a pseudomeningocele.^1,2^ When the CSF develops a direct connection with the outside environment, as in this case, it is referred to as a CSF fistula with CSF leak.^3^ Persistence of such a fistula may provide a direct conduit for bacteria to enter the meninges, causing meningitis, and the deep surgical wound, causing discitis or vertebral osteomyelitis. Intraoperative treatment of durotomies using various materials as well as postoperative CSF leak management strategies will be discussed below. In the patient described in this case, more timely and effective management of the CSF leak might have prevented catastrophic infectious complications.

### Background

#### Epidemiology

Intraoperative durotomy can occur incidentally or intentionally. When accessing intradural tumors, the dura is opened intentionally, and reapproximating via suturing is the intended plan for dural closure. If water-tight dural closure is not achieved, the risk of postoperative CSF leak is increased. Incidental durotomies often result in complex tears that may go unnoticed. Intraoperative, incidental durotomies are a common occurrence during lumbar laminectomy.^4,5,6,7^ Rates of incidental durotomy have been reported in the literature to occur from 0.5% in lumbar discectomy to 35% in a single retrospective study.^8,9^

#### Pathophysiology

Intraoperative durotomy, by definition, requires a dural tear. If cerebrospinal fluid (CSF) leaks through the dural tear into the surrounding tissue, forming a fibrous capsule, the condition is termed a pseudomeningocele (Figure 1).^1,2,10^

Figure 1 Layers involved in the formation of a pseudomeningocele, with schematic representation of nerve root entrapment at the site of dural defect

Source: David K, Rao R, Fischgrund J. Postoperative Pseudomeningocele, Hematoma, and Seroma. Musculoskeletal Key. 2016. [Available at (https://musculoskeletalkey.com/postoperative-pseudomeningocele-hematoma-and-seroma/)]

Pseudomeningoceles do not communicate with another cavity or the outside world. If the extradural fluid communicates with another cavity, such as the pleura, then it is classified as a CSF fistula. If a direct communication to the outside of the body exists, then it is considered a CSF fistula and CSF leakage can be appreciated from a wound.^3^

There is ongoing debate regarding the factors that contribute to persistent CSF fistula formation and leakage. CSF extravasation into a pseudomeningocele, if small, can be self-limited.^11^ However, if enough CSF collects in the traumatized paraspinal musculature, an abnormal connective tissue reaction can occur, hindering CSF reabsorption and leading to wound breakdown.^12,13^ If watertight closure of dura is not achieved, then firm fascial closure may reduce the risk of CSF leak. In this setting, increased epidural CSF pressure prevents CSF extravasation through the dural defect by creating an unfavorable pressure gradient. If not tightly reapproximated, dural flaps cannot remain adhered at the durotomy site and CSF leak is more likely.^14^ Both mechanisms—CSF extravasation into a pseudomeningocele and inadequate fascial closure— may contribute to the formation of pseudomeningoceles and CSF fistulas.

Table 1 Signs and Symptoms Associated with Pseudomeningoceles and CSF Fistulas

- Recurrence of low-back pain; - Recurrence of radicular pain; - Posture-related headache; - Cervical or occipital pain; - Nausea and vomiting; - Photophobia | - Cranial nerve palsy; - Tinnitus; - Palpable mass; - Delayed myelopathy; - Meningismus or other signs of meningitis

Source: Hawk MW, Kim KD. Review of spinal pseudomeningoceles and cerebrospinal fluid fistulas. Neurosurg Focus. 2000;9(1):e5. 10.3171/foc.2000.9.1.5

#### Clinical Manifestations

Intraoperative durotomy can manifest in various ways.^3^ A common sign during surgery is the pooling of clear CSF in the surgical field. Postoperatively, more severe complications may arise, such as wound dehiscence, persistent pseudomeningocele formation, meningitis, hydrocephalus, arachnoiditis, and, in rare cases, death.^15^ These complications may emerge immediately after surgery or even years later.^1^ Pseudomeningoceles typically appear as fluctuant masses that may become more pronounced with Valsalva maneuvers (Figure 2).^3,16^ Pain can sometimes be elicited by palpation of the pseudomeningocele.^17^ CSF leaks can be appreciated on inspection, as wound openings with clear and colorless fluid drainage.^18^ Some patients report recurrence of their preoperative symptoms, ranging from radiculopathy to myelopathy (i.e., spinal cord injury), presumably due to herniation of nerve tissue.^6,13,17,19–27^ Patients may also present with intracranial hypotension symptoms that include photophobia, cranial nerve palsies, and tinnitus.^28,29^

Figure 2 Photograph of a patient in the prone position, revealing a large fluctuant mass consistent with pseudomeningocele in the posterior lumbar location

Source: Hawk MW, Kim KD. Review of spinal pseudomeningoceles and cerebrospinal fluid fistulas. Neurosurg Focus. 2000;9(1):e5. 10.3171/foc.2000.9.1.5

#### Diagnosis

##### MRI

Diagnosis is confirmed via spinal MRI with history and physical examination to narrow the differential. A region of hypointensity on T1 weighted images and hyperintensity on T2 weighted images, consistent with a fluid collection, is seen (Figure 3).^25,30^ MRI can also help delineate the location of communication with the dura.

Figure 3 Sagittal T1 (left) and T2 (right) weighted MRI showing a large dorsal fluid collection contiguous with the subarachnoid space

Source: Hawk MW, Kim KD. Review of spinal pseudomeningoceles and cerebrospinal fluid fistulas. Neurosurg Focus. 2000;9(1):e5. 10.3171/foc.2000.9.1.5

##### Beta-2 Transferrin

If a CSF leak is present and clear fluid is visible from a wound defect, the fluid can be analyzed for beta-2 transferrin, which is a protein found only in CSF.^31^ Less than 1 mL is needed to test for its presence. By comparison, serum and other body fluids have only a beta-1 transferrin band (Figure 4).^32^

Figure 4 Nasal Fluid Positive for Beta-2 Transferrin Suggesting CSF Source

Source: Normansell DE, Stacy EK, Booker CF, Butler TZ. Detection of beta-2 transferrin in otorrhea and rhinorrhea in a routine clinical laboratory setting. Clin Diagn Lab Immunol. 1994;1(1):68–70. 10.1128/cdli.1.1.68-70.1994 7496925

### Intraoperative Management

When a dural violation is recognized, primary closure should be attempted to prevent future complications. The goal is “watertight” closure of the dura,^33^ but this goal can be difficult to achieve, especially for incidental intraoperative durotomies, as the tear can occur at an inaccessible location. For this reason, most argue that it is sufficient to contain neural elements and prevent pseudomeningoceles or CSF fistulas/leaks. If a tear is not accessible, then observation, sealants, or CSF diversion maneuvers can be used.^34,35^ It is helpful to organize primary repair strategies into 3 categories: sutures, sealants, and patches/grafts.^8,36–40^ Currently, no official consensus exists on the ideal approach.

#### Sutures

Four commonly used suture materials include nylon, polypropylene, polytetrafluoroethylene, and silk. All these materials are non-absorbable and elicit minimal to no acute inflammatory reaction, which is the goal in this setting.^22,41^ One study found that in a small linear incision, simple interrupted silk sutures were superior to running, running locked, or interrupted vertical mattress techniques.^42^ However, another study found no difference in the risk of CSF leak between simple running and interrupted running sutures with polypropylene.^43^

A biomechanical study found that a mean CSF peak pressure of 34 cm H_2_O can be observed before CSF leakage with polytetrafluoroethylene, compared with only 21 cm H_2_O for nylon. This superiority was consistent across suturing techniques.^44^ Another study showed that polypropylene had a higher mean pressure threshold than nylon in cadaveric specimens.^45^ No studies currently exist that directly compare polytetrafluoroethylene and polypropylene. Ultimately, deciding on the best suture material or technique remains challenging. We advocate for using the material with which one is most comfortable and has had the most success, as surgeon experience has been shown to favorably impact outcomes.^46^

After completing a primary closure, the surgeon should test their suturing for persistent CSF leak using a Valsalva maneuver (VM), where the anesthesiologist increases intrathoracic pressure. The VM can be performed by switching the ventilator to manual ventilation, and with the adjustable pressure-limiting valve fully closed, the anesthesiologist increases fresh gas flow and squeezes the breathing circuit bag for 15-20 seconds to achieve an intrathoracic pressure around 40 mmHg.^47^ One should be mindful that rare complications of this maneuver have been reported, ranging from stroke and retinopathy to pneumothorax.^47^ Clinical judgment should prevail when deciding whether to perform a VM.

#### Patches/Grafts

If primary closure of an intraoperative durotomy is not feasible, because the location is too lateral or neural elements would become compressed, then dural patches/grafts can be employed. Ideally, the patch/graft material should restore the continuity of the dura mater, minimize CSF leak, mimic the compliance of dura, and be biologically inert.^48^ Currently, the options fall into four categories: autograft, allograft (i.e., cadaveric dura), xenograft (animal-derived), and synthetic materials. In the autologous category, the options typically used in spinal surgery include fascia lata and muscle.

One of the most frequently used products is a porous type 1 collagen matrix manufactured from bovine deep flexor tendon and engineered to remove antigenic components.^49^ An interesting property of this material is that it has some secondary hemostatic capabilities as its porosity allows platelets and fibroblasts to infiltrate it and create fibrin clots and lay natural collagen fibers, which are believed to aid in preventing CSF leakage and aiding dural repair. This product also resorbs completely within 1 year,^50^ with no inflammatory response, a 1.9% infection rate, and a 2.1% leakage rate.^51^

#### Sealants

If a CSF leak persists after attempted primary closure with a patch or graft, a sealant can be placed over the area of the leak. Despite animal studies suggesting sealant alone can withstand high hydrostatic pressures,^52–54^ some remain in situ for only 10-14 days;^55^ thus, sealants alone may be inadequate but can be used to supplement a patch, graft, or suture repair.

Commercially available sealants fall into two categories as either synthetic, consisting of polyethylene glycol (PEG)-based polymers, or fibrin-based from allogenic or autogenic fibrinogen combined with thrombin and other hemostatic factors. Synthetic, PEG-based sealants work as hydrogels, absorbing fluid and swelling to minimize mass on the spine.^56,57^ One prospective, multicenter, randomized controlled trial comparing a synthetic sealant to standard-of-care closure during spinal surgery showed that the sealant improved the percentage of patients with intraoperative watertight closure (99% versus 79%).^58^ In a larger, nonrandomized, two-armed prospective study, the same product was confirmed as safe, although its 90-day outcomes did not significantly differ from those of other products.^59^ Only this PEG-based sealant has been approved by the Food and Drug Administration (FDA) as a secondary agent for dural closure in the spine.^60^

### Postoperative Pseudomeningocele/CSF Fistula/Leak Management

#### Conservative Approach

If an intraoperative spinal durotomy cannot be closed “watertight” or the patient exhibits symptoms, preventing pseudomeningocele formation or controlling the CSF leak depends on manipulating differences in subarachnoid and epidural pressure.^61^ To this end, Trendelenburg positioning is traditionally prescribed after lumbar dural tears^62^ because the upright position increases the hydrostatic pressure of the CSF and may worsen leakage.^63^ Interestingly, the data supporting this approach are limited to series describing patients successfully treated with prolonged bed rest without a control group of alternative options.^64^ A recent meta-analysis reported that early mobilization reduced pulmonary complications, when compared with prolonged bed rest, among patients who underwent primarily closed durotomies. No significant difference in the incidence of CSF leak or the need for additional surgical durotomy repair was appreciated. Surgeons should use bed rest and Trendelenburg positioning with caution, given the risk of postoperative complications.^65^ Nonetheless, several surveys have shown that up to 89% of spine surgeons still favor prolonged bed rest in this patient population.^66–69^

Direct pressure at the durotomy site with a pressure dressing or brace may counteract egress through the area of least resistance.^39^ We argue that it is reasonable to try Trendelenburg positioning and direct pressure at the site of durotomy for a short course of 1 to 3 days in someone with a suspected lumbar durotomy. The role of antibiotic therapy for CSF fistulas and pseudomeningoceles is not clear. However, an analysis of published reports suggested that antibiotics do not decrease the short- or long-term incidence of meningitis among patients with cranial CSF fistulas or pseudomeningoceles.^70^

If symptoms continue or worsen, as in this case, escalation of care to non-conservative therapy should begin. These non-conservative options include epidural blood patch, CSF diversion measures, and reoperation for primary closure attempt or reattempt. In this case, it is unclear why the surgeon waited until POD 25 to readmit the patient, and even then, did not reimage the patient, apparently satisfied by not finding a visible dural defect during wound exploration. Several previous (https://psnet.ahrq.gov/web-mm/infection-after-carpal-tunnel-surgery) PSNet cases (https://psnet.ahrq.gov/web-mm/errors-managing-open-wound-elbow-leading-multiple-complications-and-operations) have illustrated how providers may fail to escalate treatment for post-procedural complications in a timely manner when they lack knowledge or experience, have ineffective communication (https://psnet.ahrq.gov/web-mm/under-pressure-delayed-diagnosis-compartment-syndrome-after-lower-leg-fracture) or diffusion of responsibility among team members, or “anchor (https://psnet.ahrq.gov/web-mm/do-not-miss-sepsis-needles-viral-haystacks)” on a single diagnosis or treatment strategy despite evolving evidence of its failure.

#### Non-Conservative Approach

##### Epidural Blood Patch

Epidural blood patch (EBP) is a procedure in which the patient’s own blood is injected into the epidural space. It is thought that the blood forms a clot over the dural tear, allowing healing of the dura. The EBP also raises extradural pressure relative to the subarachnoid pressure to decrease the efflux of CSF.^71^

##### CSF Diversion

A large pseudomeningocele is best treated by a combination of primary closure and implantation of a subarachnoid drain.^72^ These drains are efficacious at an output rate of 5-10 mL/hr for 3-5 days, as a primary tool or supplement to other measures.^73^ However, lumbar subarachnoid drainage has been reported to have a complication rate of up to 44% with symptoms ranging from headache and nerve root pain to subdural hematoma, pneumocephalus, and meningitis.^74^ These symptoms are important to consider when choosing to use a lumbar subarachnoid drain.

Lastly, there have been reports of a ventriculoperitoneal or lumboperitoneal shunt being used successfully to treat a pseudomeningocele and CSF fistula/leak.^75–78^ However, this approach should only be considered as a last resort, after an attempt/reattempt at primary closure has failed.

### Approaches to Improving Patient Safety

Avoidance of a durotomy, if not in the plan of the operation, is critical. The necessary dissections should precede each Kerrison rongeur bite during a laminectomy to ensure that the dura mater does not come between the footplate of the rongeur and bone. The movement of the drill during a laminectomy should be directed laterally so that even with a slip, a dural tear may be avoided. An instrument should cover the exposed dura during the drilling. When a dural violation is appreciated, primary closure should be attempted to prevent future complications. The goal is “watertight” closure of the dura.^33^ Extending the laminectomy may be necessary to gain better exposure to repair the dura, while using magnification via loupes or a microscope. For durotomies that occur in inaccessible areas, such as far-lateral durotomies, a small plug of muscle or fat may be introduced through a more medial, intentional durotomy and pulled into the defect (Figure 5).^8^

Figure 5 A Schematic Drawing of Mayfield’s Midline Durotomy in Which a Far-Lateral Dural Tear is Repaired

Source: Hawk MW, Kim KD. Review of spinal pseudomeningoceles and cerebrospinal fluid fistulas. Neurosurg Focus. 2000;9(1):e5. 10.3171/foc.2000.9.1.5

If a patient with a suspected lumbar durotomy is exhibiting symptoms, it is reasonable to try Trendelenburg positioning for a short course of 1 to 3 days. Direct pressure at the site of durotomy with a pressure dressing or brace may counteract egress through the area of least resistance.^39^ Kim et al published a case report where a polycarbonate face mask was used to apply pressure on a refractory pseudomeningocele,^39^ leading to resolution. One should suspect a CSF leak if symptoms persist; imaging and laboratory testing should be considered for confirmation. If a durotomy went unnoticed intraoperatively, or a “watertight” closure could not be obtained, and the patient remains symptomatic after several conservative therapies have been employed, then timely escalation to non-conservative therapy is essential. Failure to do so in this case suggests implicit bias, perhaps due to the patient’s age, cultural or communication barriers, or perceived lack of adherence to bed rest. Non-conservative therapies include epidural blood patch and lumbar subarachnoid drain placement. If these measures continue to fail, reoperation to obtain a primary closure should be attempted or reattempted, and in rare cases, placement of a ventriculo/lumboperitoneal shunt should be considered.

## Take-Home Points

- The best offense is a good defense and avoidance of a durotomy, if not in the plan of the surgery, is key to preventing complications.
- If a dural violation occurs, the primary goal should be achieving a “watertight” closure. This can be done using patches, grafts, and sealants to reinforce the primary repair.
- In cases where a watertight closure is not achieved, or if a durotomy goes unnoticed and the patient develops symptoms, immediate management of the CSF leak is crucial.
- Management of a CSF leak should begin conservatively, with bed rest and local pressure dressings. If these measures fail, escalate care promptly to include interventions such as an epidural blood patch or lumbar subarachnoid drain placement. Prolonged bed rest at home is not appropriate.
- If all measures continue to fail, a reoperation to achieve primary closure is needed to avoid severe complications. In rare cases, the placement of a ventriculoperitoneal or lumboperitoneal shunt may be considered.

## References

1 Miller PR, Elder FW. Meningeal pseudocysts (meningocele spurius) following laminectomy. Report of ten cases. J Bone Joint Surg Am. 1968;50(2):268–276. 10.2106/00004623-196850020-00005 5642816
2 Pagni CA, Cassinari V, Bernasconi V. Meningocele spurius following hemilaminectomy in a case of lumbar discal hernia. J Neurosurg. 1961;18:709–710. 10.3171/jns.1961.18.5.0709 13732071
3 Hawk MW, Kim KD. Review of spinal pseudomeningoceles and cerebrospinal fluid fistulas. Neurosurg Focus. 2000;9(1):e5. 10.3171/foc.2000.9.1.5
4 Jones AA, Stambough JL, Balderston RA, . Long-term results of lumbar spine surgery complicated by unintended incidental durotomy. Spine (Phila Pa 1976). 1989;14(4):443–446. 10.1097/00007632-198904000-00021 2718049
5 Lee KS, Hardy IM. Postlaminectomy lumbar pseudomeningocele: report of four cases. Neurosurgery. 1992;30(1):111–114. 10.1227/00006123-199201000-00020 1738437
6 O’Connor D, Maskery N, Griffiths WE. Pseudomeningocele nerve root entrapment after lumbar discectomy. Spine (Phila Pa 1976). 1998;23(13):1501–1502.10.1097/00007632-199807010-00014 9670405
7 Oppel F, Schramm J, Schirmer M, . Results and Complicated Course after Surgery for Lumbar Disc Herniation. In: Wüllenweber R, Brock M, Hamer J, Klinger M, Spoerri O, eds. Lumbar Disc Adult Hydrocephalus. Vol 4. Advances in Neurosurgery. Springer Berlin Heidelberg; 1977:36–51. 10.1007/978-3-642-66578-3_9
8 Mayfield FH, Kurokawa K. Watertight closure of spinal dura mater. Technical note. J Neurosurg. 1975;43(5):639–640. 10.3171/jns.1975.43.5.0639 1102634
9 Rodriguez-Olaverri JC, Zimick NC, Merola A, . Comparing the clinical and radiological outcomes of pedicular transvertebral screw fixation of the lumbosacral spine in spondylolisthesis versus unilateral transforaminal lumbar interbody fusion (TLIF) with posterior fixation using anterior cages. Spine (Phila Pa 1976). 2008;33(18):1977–1981.10.1097/BRS.0b013e31817ecc01 18708930
10 David K, Rao R, Fischgrund J. Postoperative Pseudomeningocele, Hematoma, and Seroma. Musculoskeletal Key. 2016. Accessed November 6, 2024. [Free full text (https://musculoskeletalkey.com/postoperative-pseudomeningocele-hematoma-and-serom)]
11 Tsuji H, Handa N, Handa O, . Postlaminectomy ossified extradural pseudocyst. Case report. J Neurosurg. 1990;73(5):785–787. 10.3171/jns.1990.73.5.0785 2213171
12 Bhatoe HS. Postoperative lumbar pseudomeningocele. J Indian Med Assoc. 1995;93(7):280, 282. [PubMed citation (https://pubmed.ncbi.nlm.nih.gov/8576597/)]8576597
13 Goodman SJ, Gregorius FK. Cervical pseudomeningocele after laminectomy as a cause of progressive myelopathy. Bull Los Angeles Neurol Soc. 1974;39(3):121–127. [PubMed citation (https://pubmed.ncbi.nlm.nih.gov/4850947/)]4850947
14 Mammadkhanli O, Elbir C, Hanalioglu S, . Subfascial drainage and clipping technique for treatment of cerebrospinal fluid leak following spinal surgery. Neurosciences (Riyadh). 2020;25(1):50–54. [Free full text (https://pmc.ncbi.nlm.nih.gov/articles/PMC8015620/)]31982895
15 Couture D, Branch CL. Spinal pseudomeningoceles and cerebrospinal fluid fistulas. Neurosurg Focus. 2003;15(6):E6. 10.3171/foc.2003.15.6.6
16 Rocca A, Turtas S, Pirisi A, . Iatrogenic lumbar pseudomeningocele. Zentralbl Neurochir. 1986;47(4):311–315. [Available at (https://www.sciencedirect.com/science/article/abs/pii/0090301988901279)]3564761
17 Aldrete JA, Ghaly R. Postlaminectomy pseudomeningocele. An unsuspected cause of low back pain. Reg Anesth. 1995;20(1):75–79. [Available at (https://rapm.bmj.com/content/20/1/75)]7727333
18 Huff T, Tadi P, Weisbrod LJ, . Neuroanatomy, Cerebrospinal Fluid. In: StatPearls. StatPearls Publishing; 2024. Accessed July 20, 2024. [Free full text (http://www.ncbi.nlm.nih.gov/books/NBK470578/)]
19 Cobb C, Ehni G. Herniation of the spinal cord into an iatrogenic meningocele. Case report. J Neurosurg. 1973;39(4):533–536. 10.3171/jns.1973.39.4.0533 4730343
20 Maiuri F, Corriero G, Giamundo A, . Postoperative cervical pseudomeningocele. Neurochirurgia (Stuttg). 1988;31(1):29–31. 10.1055/s-2008-1053895 3347335
21 Burres KP, Conley FK. Progressive neurological dysfunction secondary to postoperative cervical pseudomeningocele in a C-4 quadriplegic. Case report. J Neurosurg. 1978;48(2):289–291. 10.3171/jns.1978.48.2.0289 624977
22 Hadani M, Findler G, Knoler N, . Entrapped lumbar nerve root in pseudomeningocele after laminectomy: report of three cases. Neurosurgery. 1986;19(3):405–407. 10.1227/00006123-198609000-00011 3762888
23 Helle T, Conley FK. Postoperative Cervical pseudomeningocele as a cause of delayed myelopathy. Neurosurgery. 1981;9(3):314–316. [Available at (https://journals.lww.com/7301076.pmid)]7301076
24 Horowitz SW, Azar-Kia B, Fine M. Postoperative cervical pseudomeningocele. AJNR Am J Neuroradiol. 1990;11(4):784. [Free full text (https://pmc.ncbi.nlm.nih.gov/articles/PMC8331626/)]2114768
25 Hosono N, Yonenobu K, Ono K. Postoperative cervical pseudomeningocele with herniation of the spinal cord. Spine (Phila Pa 1976). 1995;20(19):2147–2150. 10.1097/00007632-199510000-00014 8588173
26 Rinaldi I, Hodges TO. Iatrogenic lumbar meningocoele: report of three cases. J Neurol Neurosurg Psychiatry. 1970;33(4):484–492. [Free full text (https://pmc.ncbi.nlm.nih.gov/articles/PMC493505/)]4918460
27 Wilkinson HA. Nerve-root entrapment in “traumatic” extradural arachnoid cyst. J Bone Joint Surg Am. 1971;53(1):163–166. [Available at (https://journals.lww.com/jbjsjournal/citation/1971/53010/nerve_root_entrapment_in__traumatic__extradural.19.aspx)]4322076
28 Bell WE, Joynt RJ, Sahs AL. Low spinal fluid pressure syndromes. Neurology. 1960;10:512–521. 10.1212/wnl.10.5.512 13798523
29 Hochman MS, Naidich TP, Kobetz SA, . Spontaneous intracranial hypotension with pachymeningeal enhancement on MRI. Neurology. 1992;42(8):1628–1630. 10.1212/wnl.42.8.1628 1641162
30 Schumacher HW, Wassmann H, Podlinski C. Pseudomeningocele of the lumbar spine. Surg Neurol. 1988;29(1):77–78. 10.1016/0090-3019(88)90127-9 3336842
31 Ryall RG, Peacock MK, Simpson DA. Usefulness of beta 2-transferrin assay in the detection of cerebrospinal fluid leaks following head injury. J Neurosurg. 1992;77(5):737–739. 10.3171/jns.1992.77.5.0737 1403116
32 Normansell DE, Stacy EK, Booker CF, Butler TZ. Detection of beta-2 transferrin in otorrhea and rhinorrhea in a routine clinical laboratory setting. Clin Diagn Lab Immunol. 1994;1(1):68–70. [Free full text (https://pmc.ncbi.nlm.nih.gov/articles/PMC368198/)]7496925
33 Barth M, Tuettenberg J, Thomé C, Weiss C, Vajkoczy P, Schmiedek P. Watertight dural closure: is it necessary? A prospective randomized trial in patients with supratentorial craniotomies. Neurosurgery. 2008;63(4 Suppl 2):352–358; discussion 358. 10.1227/01.NEU.0000310696.52302.99
34 Hannallah D, Lee J, Khan M, Donaldson WF, Kang JD. Cerebrospinal fluid leaks following cervical spine surgery. J Bone Joint Surg Am. 2008;90(5):1101–1105. 10.2106/JBJS.F.01114 18451403
35 Kitchel SH, Eismont FJ, Green BA. Closed subarachnoid drainage for management of cerebrospinal fluid leakage after an operation on the spine. J Bone Joint Surg Am. 1989;71(7):984–987. [Available at (https://journals.lww.com/2760094.pmid)]2760094
36 Eismont FJ, Wiesel SW, Rothman RH. Treatment of dural tears associated with spinal surgery. J Bone Joint Surg Am. 1981;63(7):1132–1136. [Available at (https://journals.lww.com/7024283.pmid)]7024283
37 Foyt D, Johnson JP, Kirsch AJ, Bruce JN, Wazen JJ. Dural closure with laser tissue welding. Otolaryngol Head Neck Surg. 1996;115(6):513–518. 10.1016/S0194-59989670005-0 8969756
38 Levy DI, Sonntag VK. Titanium dural clip testing. Technical note. J Neurosurg. 1994;81(6):947–949. 10.3171/jns.1994.81.6.0947 7965130
39 Kerr E, Ripul P, Kim KD. Refractory Cervical Spinal Pseudomeningocele Successfully Treated with a Polycarbonate Face Mask: Technical Note. JSM Neurosurgery and Spine. 2014;2(1):1011. [Free full text (https://www.jscimedcentral.com/jounal-article-info/JSM-Neurosurgery-and-Spine-/Refractory-Cervical-Spinal-Pseudomeningocele-Successfully-Treated-with-a-Polycarbonate-Face-Mask%3A-Technical-Note-5215)]
40 Shimada Y, Hongo M, Miyakoshi N, . Dural substitute with polyglycolic acid mesh and fibrin glue for dural repair: technical note and preliminary results. J Orthop Sci. 2006;11(5):454–458. 10.1007/s00776-006-1044-7 17013732
41 Chu CC, Pratt L, Zhang L, Hsu A, Chu A. A comparison of a new polypropylene suture with Prolene. J Appl Biomater. 1993;4(2):169–181. 10.1002/jab.770040209 10148624
42 Megyesi JF, Ranger A, MacDonald W, Del Maestro RF. Suturing technique and the integrity of dural closures: an in vitro study. Neurosurgery. 2004;55(4):950–954; discussion 954–955. 10.1227/01.neu.0000138441.07112.1b 15458604
43 Ebel F, Wanderer S, Beck J, Raabe A, Ulrich CT. The Optimal Dura Closure Technique and Material – An In-Vitro Evaluation. J Neurol Surg A Cent Eur Neurosurg. 2017;78(S 01):S1–S22. [Available at (https://www.thieme-connect.com/products/ejournals/abstract/10.1055/s-0037-1603847?device=desktop&lang=en)]
44 Ghobrial GM, Maulucci CM, Viereck MJ, . Suture Choice in Lumbar Dural Closure Contributes to Variation in Leak Pressures: Experimental Model. Clin Spine Surg. 2017;30(6):272–275. 10.1097/BSD.0000000000000169 28632550
45 Bakhsheshian J, Strickland BA, Patel NN, . The use of a novel perfusion-based cadaveric simulation model with cerebrospinal fluid reconstitution comparing dural repair techniques: a pilot study. Spine J. 2017;17(9):1335–1341. 10.1016/j.spinee.2017.04.007 28412565
46 Kelz RR, Sellers MM, Niknam BA, . A National Comparison of Operative Outcomes of New and Experienced Surgeons. Ann Surg. 2021;273(2):280–288. [Free full text (https://pmc.ncbi.nlm.nih.gov/articles/PMC6898745/)]31188212
47 Kumar CM, Van Zundert AAJ. Intraoperative Valsalva maneuver: a narrative review. Can J Anaesth. 2018;65(5):578–585. 10.1007/s12630-018-1074-6 29368315
48 MacEwan MR, Kovacs T, Osbun J, Ray WZ. Comparative analysis of a fully-synthetic nanofabricated dura substitute and bovine collagen dura substitute in a large animal model of dural repair. Interdisciplinary Neurosurgery. 2018;13:145–150. 10.1016/j.inat.2018.05.001
49 Integra. Accessed November 6, 2024. [Available at (https://www.sciencedirect.com/topics/engineering/integra)]
50 Haq I, Cruz-Almeida Y, Siqueira EB, . Postoperative fibrosis after surgical treatment of the porcine spinal cord: a comparison of dural substitutes. Invited submission from the Joint Section Meeting on Disorders of the Spine and Peripheral Nerves, March 2004. J Neurosurg Spine. 2005;2(1):50–54. 10.3171/spi.2005.2.1.0050 15658126
51 Integra. Integra Promotional Material #0069447- 3-EN. Accessed November 6, 2024. [Free full text (https://products.integralife.com/file/general/1518550095.pdf)]
52 Epstein NE, Hollingsworth R. Anterior cervical micro-dural repair of cerebrospinal fluid fistula after surgery for ossification of the posterior longitudinal ligament. Technical note. Surg Neurol. 1999;52(5):511–514. 10.1016/s0090-3019(99)00135-4 10595772
53 Cain JE, Rosenthal HG, Broom MJ, . Quantification of leakage pressures after durotomy repairs in the canine. Spine (Phila Pa 1976). 1990;15(9):969–970. 10.1097/00007632-199009000-00024 2259990
54 Pomeranz S, Constantini S, Umansky F. The use of fibrin sealant in cerebrospinal fluid leakage. Neurochirurgia (Stuttg). 1991;34(6):166–169.10.1055/s-2008-1052082 1775205
55 Tisseel. Baxter Advanced Surgery. Accessed November 6, 2024. [Free full text (https://advancedsurgery.baxter.com/tisseel)]
56 Mulder M, Crosier J, Dunn R. Cauda equina compression by hydrogel dural sealant after a laminotomy and discectomy: case report. Spine (Phila Pa 1976). 2009;34(4):E144–E148. 10.1097/BRS.0b013e31818d5427 19214084
57 Tseng WL, Xiao F. Duraseal thecal sac compression after lumbar discectomy causing radiculopathy. Spine J. 2015;15(8):1892–1893. 10.1016/j.spinee.2015.03.048 25843249
58 Wright NM, Park J, Tew JM, . Spinal sealant system provides better intraoperative watertight closure than standard of care during spinal surgery: a prospective, multicenter, randomized controlled study. Spine (Phila Pa 1976). 2015;40(8):505–513. 10.1097/BRS.0000000000000810 25646746
59 Kim KD, Ramanathan D, Highsmith J, . DuraSeal Exact Is a safe adjunctive treatment for durotomy in spine: postapproval study. Global Spine J. 2019;9(3):272–278. 10.1177/2192568218791150 31192094
60 FDA. Premarket Approval (PMA). US Food & Drug Administration. Accessed November 6, 2024. [Free full text (https://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfpma/pma.cfm?id=P080013S028)]
61 Fang Z, Tian R, Jia YT, . Treatment of cerebrospinal fluid leak after spine surgery. Chin J Traumatol. 2017;20(2):81–83. [Free full text (https://pmc.ncbi.nlm.nih.gov/articles/PMC5392710/)]28336418
62 Hodges SD, Humphreys SC, Eck JC, . Management of incidental durotomy without mandatory bed rest. A retrospective review of 20 cases. Spine (Phila Pa 1976). 1999;24(19):2062–2064. 10.1097/00007632-199910010-00017 10528385
63 Khan MH, Rihn J, Steele G, . Postoperative management protocol for incidental dural tears during degenerative lumbar spine surgery: a review of 3,183 consecutive degenerative lumbar cases. Spine (Phila Pa 1976). 2006;31(22):2609–2613. 10.1097/01.brs.0000241066.55849.41 17047553
64 Winter F, Hasslinger S, Frueh A, . Incidence, risk factors, and treatment of incidental durotomy during decompression in degenerative lumbar spine conditions. J Neurosurg Sci. 2023;67(4):507–511. 10.23736/S0390-5616.21.05404-7 34763388
65 Gomes FC, Larcipretti ALL, Elvir FAR, . Early ambulation versus prolonged bed rest for incidental durotomies in spine procedures: a systematic review and meta-analysis. Neurosurg Rev. 2023;46(1):310. 10.1007/s10143-023-02201-2 37989906
66 Oitment C, Aref M, Almenawar S, . Spinal Dural Repair: A Canadian Questionnaire. Global Spine Journal. 2018;8(4):359–364. 10.1177/2192568217724132 29977720
67 Clajus C, Stockhammer F, Rohde V. The intra- and postoperative management of accidental durotomy in lumbar spine surgery: results of a German survey. Acta Neurochir (Wien). 2015;157(3):525–530. 10.1007/s00701-014-2325-0 25577453
68 Lewandrowski KU, Hellinger S, De Carvalho PST, . Dural tears during lumbar spinal endoscopy: surgeon skill, training, incidence, risk factors, and management. Int J Spine Surg. 2021;15(2):280–294. 10.14444/8038 33900986
69 Gautschi OP, Stienen MN, Smoll NR, . Incidental durotomy in lumbar spine surgery–a three-nation survey to evaluate its management. Acta Neurochir (Wien). 2014;156(9):1813–1820. 10.1007/s00701-014-2177-7 25047813
70 Eljamel MS. Antibiotic prophylaxis in unrepaired CSF fistulae. Br J Neurosurg. 1993;7(5):501–505. 10.3109/02688699308995072 8267888
71 McCormack BM, Taylor SL, Heath S, . Pseudomeningocele/CSF fistula in a patient with lumbar spinal implants treated with epidural blood patch and a brief course of closed subarachnoid drainage. A case report. Spine (Phila Pa 1976). 1996;21(19):2273–2276. 10.1097/00007632-199610010-00019 8902974
72 Weng YJ, Cheng CC, Li YY, . Management of giant pseudomeningoceles after spinal surgery. BMC Musculoskelet Disord. 2010;11:53. 10.1186/1471-2474-11-53 20302667
73 Shapiro SA, Scully T. Closed continuous drainage of cerebrospinal fluid via a lumbar subarachnoid catheter for treatment or prevention of cranial/spinal cerebrospinal fluid fistula. Neurosurgery. 1992;30(2):241–245. 10.1227/00006123-199202000-00015 1545892
74 Açikba? SC, Akyüz M, Kazan S, . Complications of closed continuous lumbar drainage of cerebrospinal fluid. Acta Neurochir (Wien). 2002;144(5):475–480. 10.1007/s007010200068 12111503
75 Duthel R, Nuti C, Motuo-Fotso MJ, . [Complications of lumboperitoneal shunts. A retrospective study of a series of 195 patients (214 procedures)]. Neurochirurgie. 1996;42(2):83–89; discussion 89–90. [PubMed citation (https://pubmed.ncbi.nlm.nih.gov/8952901/)]8952901
76 James HE, Tibbs PA. Diverse clinical applications of percutaneous lumboperitoneal shunts. Neurosurgery. 1981;8(1):39–42. 10.1227/00006123-198101000-00008 7207771
77 Katz SS, Savitz MH, Osei C, . Successful treatment by lumboperitoneal shunting of a spinal subclavicular fistula following thoracotomy. Neurosurgery. 1982;11(6):795–796. 10.1227/00006123-198212000-00014 7162573
78 Kitchen N, Bradford R, Platts A. Occult spinal pseudomeningocele following a trivial injury successfully treated with a lumboperitoneal shunt: a case report. Surg Neurol. 1992;38(1):46–49. 10.1016/0090-3019(92)90211-5 1615374