# References

Andreasen A. 1995. Marketing social change: Changing behavior to promote health, social development, and the environment. San Francisco. Jossey-Bass.
Backer TE, Rogers EM, Sopory P. 1992. Designing health communication campaigns: What works. Thousand Oaks, CA. Sage.
Baker DW. 2006. Literacy and Cognitive Measures Both Associated with Mortality. Unpublished raw data.
Baker DW, Gazmararian JA, Williams MV, Scott T, Parker RM, Green D, et al. Functional health literacy and the risk of hospital admission among Medicare managed care enrollees. American Journal of Public Health. 2002;92(8):1278-83. [pmid: 12144984].
Baker DW, Parker RM, Williams MV, Clark WS. Health literacy and the risk of hospitalization. Journal of General Internal Medicine. 1998;13(12):791-798. [pmid: 9844076].
Baker DW, Parker RM, Williams MV, Clark WS, Nurss J. The relationship of patient reading ability to self-reported health and use of health services. American Journal of Public Health. 1997;87(6):1027-1030. [pmid: 9224190].
Baker DW, Parker RM, Williams MV, Coates WC, Pitkin K. Use and effectiveness of interpreters in an emergency department. JAMA. 1996;275(10):783-788. [pmid: 8598595].
Baker DW, Wolf MS, Feinglass J, Thompson JA, Gazmararian JA, Huang J. Health literacy and mortality among elderly persons. Archives of Internal Medicine. 2007;167(14):1503-1509. [pmid: 17646604].
Berkman ND, DeWalt DA, Pignone MP, Sheridan SL, Lohr KN, Lux L, et al. 2004. Literacy and Health Outcomes. Evidence Report/Technology Assessment No 87 (Prepared by RTI International-University of North Carolina Evidence-based Practice Center). Rockville, MD. Agency for Healthcare Research and Quality.
Bradshaw M, Tomany-Korman SC, Flores G. in press. Language barriers to prescriptions for patients with limited English proficiency: A survey of pharmacies. Pediatrics.
Brown SC, Park DC. Theoretical models of cognitive aging and implications for translational research in medicine. The Gerontologist. 2003;43(Special Issue I):57-67. [pmid: 12637690].
Centers for Disease Control and Prevention. 2001. CDCynergy [CD-ROM]. Atlanta, GA.
Cooper LA, Beach MC, Clever SL. Schwartzberg JG, VanGeest JB, Wang CC, editors. Participatory decision-making in the medical encounter and its relationship to patient literacy. Understanding Health Literacy. AMA Press. 2005:141-154.
David RA, Rhee M. The impact of language as a barrier to effective health care in an underserved urban Hispanic community. Mount Sinai Journal of Medicine. 1998;65:393-397. [pmid: 9844369].
Davis TC, Holcombe RF, Berkel HJ, Pramanik S, Divers SG. Informed consent for clinical trials: a comparative study of standard versus simplified forms. Journal of the National Cancer Institute. 1998;90(9):668-674. [pmid: 9586663].
Davis TC, Wolf MS, Bass PF III, Middlebrooks M, Kennen E, Baker DW, et al. Low Literacy Impairs Comprehension of Prescription Drug Warning Labels. Journal of General Internal Medicine. 2006;21(8):847-851. [pmid: 16881945].
DeWalt DA, Malone RM, Bryant ME, Kosnar MC, Corr KE, Rothman RL, et al. A heart failure self-management program for patients of all literacy levels: A randomized, controlled trial. BMC Health Services Research. 2006;6:30. [pmid: 16533388].
Ebden P, Bhatt A, Carey OJ, Harrison B. The bilingual consultation. Lancet. 1988;13:347. [pmid: 2893151].
Eva KW, Cunnington JPW, Reiter HI, Keane DR, Norman GR. How can I know what I don’t know? Poor self assessment in a well-defined domain. Advances in Health Sciences Education. 2004;9:211-224. [pmid: 15316272].
Fang M, Machtinger EL, Wang F, Schillinger D. Health literacy and anticoagulation-related outcomes among patients taking warfarin. Journal of General Internal Medicine. 2006;21(8):841-846. [pmid: 16881944].
Farrelly MC, Davis KC, Haviland L, Messeri P, Healton CG. Evidence of a dose-response relationship between “truth” anti-smoking ads and youth smoking prevalence. American Journal of Public Health. 2005;95:425-431. [pmid: 15727971].
Flores G. Providing culturally competent pediatric care: Integrating pediatricians, institutions, families, and communities into the process. Journal of Pediatrics. 2003;143(1):1-2. [pmid: 12915812].
Flores G, Abreu M, Olivar MA, Kastner B. Access barriers to health care for Latino children. Archives of Pediatrics and Adolescent Medicine. 1998;152:1119-1125. [pmid: 9811291].
Freeman H. Patient navigation: A community centered approach to reducing cancer mortality. Journal of Cancer Education. 2006;21(1):S11-S14. [pmid: 17020496].
Gustafson DH, Hawkins R, Boberg E, Pingree S, Serlin RE, Graziano F, Chan CL. Impact of a patient-centered, computer-based health information/support system. American Journal of Preventive Medicine. 1999;16(1):1-9. [pmid: 9894548].
Haven J, Burns A, Herring D, Britten P. MyPyramid.gov provides consumers with practical nutrition information at their fingertips. Journal of Nutrition Education and Behavior. 2006;38:S153-154. [pmid: 17116593].
Hayes BK, Hulleat LA, Keil FC. 2004. Mechanisms Underlying the Illusion of Explanatory Depth. Manuscript submitted for publication.
Hentges EJ. Development of the MyPyramid food guidance system. Journal of Nutrition Education and Behavior. 2006;38:S77.
Hibbard JH, Greene J, Tusler M. 2005. Screening Medicare Beneficiaries for Health Literacy: Is a Short Screening Test Feasible?. (Publication I.D. 2005-08). Washington, DC. AARP Public Policy Institute.
Hibbard JH, Greene J, Tusler M. 2006. An Assessment of Beneficiary Knowledge of Medicare Coverage Options and the Prescription Drug Benefit. (Publication I.D. 2006-12). Washington, DC. AARP Public Policy Institute.
Hibbard JH, Mahoney ER, Stockard J, Tusler M. Development and testing of a short form of the patient activation measure. Health Services Research. 2005;40:1918-1930. [pmid: 16336556].
Hibbard JH, Peters EM, Dixon A, Tusler M. Consumer competencies and the use of comparative quality information: It isn’t just about literacy. Medical Care Research and Review. 2007;64(4):379-394. [pmid: 17684108].
Hibbard JH, Stockard J, Mahoney ER, Tusler M. Development of the Patient Activation Measure (PAM): Conceptualizing and measuring activation in patients and consumers. Health Services Research. 2004;39:1005-1026. [pmid: 15230939].
Hibbard JH, Tusler M. Assessing activation stage and employing a ‘Next Steps’ approach to supporting patient self-management. Journal of Ambulatory Care Management. 2007;30(1):2-8. [pmid: 17170632].
Huhman M, Potter LD, Wong FL, Banspach SW, Duke JC, Heitzer CD. Effects of a mass media campaign to increase physical activity among children: Year-1 results of the VERB campaign. Pediatrics. 2005;116:277-284.
Inagaki K, Hatano G. 2002. Young children’s naïve thinking about the biological world. Hove. Psychology Press.
Institute of Medicine. 2004. Health Literacy: A Prescription to End Confusion. Washington, DC. National Academies Press.
Jibala-Weiss ML, Volk RJ, Friedman LC, Granchi TS, Neff NE, Spann SJ, Robinson EK, Noriaki A, Beck JR. Preliminary testing of a just-in-time, user-defined values clarification exercise to aid lower literate women in making informed breast cancer treatment decisions. Health Expectations. 2006;9(3):218. [pmid: 16911136].
Juan WY, Gerrior S, Hiza H. MyPyramid Tracker assesses food consumption, physical activity, and energy balance status interactively. Journal of Nutrition Education and Behavior. 2006;38:S155-157. [pmid: 17116594].
Katz E, Lazarsfeld PF. 1955. Personal influence: The part played by people in the flow of mass communication. NY. The Free Press.
Kline KN. Thompson TL, Dorsey AM, Miller KL, Parrott R, editors. Popular media and health: Images, effects, and institutions. Handbook of health communication. 2003:557-582. Mahwah, NJ. Lawrence Erlbaum Associates.
Koyani SJ, Balley RW, Nall JR. 2006. Research-Based Web Design and Usability Guidelines. National Cancer Institute. Washington, DC. U.S. Department of Health and Human Services.
Kripalani S, Henderson L, Chui EY, Robertson R, Kolm P, Jacobson TA. Predictors of Medication Self-management Skill in Low-literacy Population. Journal of General Internal Medicine. 2006;21(8):852-856. [pmid: 16881946].
Kriz S, Hegarty M. Forbus K, Gentern D, Reiger T, editors. 2004. Constructing and revising mental models of a mechanical system: The role of domain knowledge in understanding external visualizations. Proceedings of the 26th Annual Conference of the Cognitive Science Society. Mahwah, NJ. Lawrence Erlbaum Associates.
Kutner M, Greenberg E, Jin Y, Paulsen C. 2006. The Health Literacy of America’s Adults: Results from the 2003 National Assessment of Adult Literacy. Washington, DC. National Center for Education Statistics.
Launer J. Taking medical histories through interpreters: practice in a Nigerian outpatient department. British Medical Journal. 1978;2:934-935. [pmid: 709137].
Lynch P, Horton S. 2002. Web Style Guide. 2nd ed. Retrieved November 20, 2006, from http://www.webstyleguide.com.
Maibach E, Parrott RL, editors. 1995. Designing health messages: Approaches from communication theory and public health practice. Thousand Oaks, CA. Sage.
McCombs M, Shaw D. The agenda-setting function of the mass media. Public Opinion Quarterly. 1973;37:62-75.
Mills C, Keil FC. Knowing the limits of one’s understanding: The development of an awareness of an illusion of explanatory depth. Journal of Experimental Child Psychology. 2004;87:1-32. [pmid: 14698687].
Mosen D, Schmittdiel J, Hibbard JH, Sobel D, Remmers C, Bellows J. Is patient activation associated with outcomes of care for adults with chronic conditions. Journal of Ambulatory Care Management. 2007;30(1):21-29. [pmid: 17170635].
National Cancer Institute. 2001. Making Health Communication Programs Work. Bethesda, MD.
National Institute of Deafness and Other Communication Disorders. 2006. Mission statement. Retrieved May 18, 2007, from http://www.nidcd.nih.gov/about/learn/mission.asp.
Neuhauser L. Participatory design for better interactive health communication: A statewide model in the U.S.A. Electronic Journal of Communication/La Revue Electronique de Communication. 2001;11. (numbers 3 and 4).
Neuhauser L, Constantine WL, Constantine NA, Sokal-Gutierrez K, Obarski SK, Clayton L, et al. Promoting prenatal and early childhood health: Evaluation of a statewide materials-based intervention for parents. American Journal of Public Health. 2007;97(10):1803-1807. [pmid: 17761569].
Neuhauser L, Kreps GL. Rethinking communication in the e-health era. Journal of Health Psychology. 2003;8(1):7-23.
Neuhauser L, Rothschild B, Rodriguez F. MyPyramid.gov: Assessment of literacy, cultural, and linguistic factors in the USDA Food Pyramid Website. Journal of Nutrition Education and Behavior. 2007;39(4):219-225. [pmid: 17606248].
Nielsen J. 2000. Designing Web Usability. Indianapolis. New Riders Publishing.
Oluwole SF, Ali AO, Adu A, Blane BP, Barlow B, Oropeza R, et al. Impact of a cancer screening program on breast cancer stage at diagnosis in a medically underserved urban community. Journal of the American College of Surgeons. 2003;196(2):180-188. [pmid: 12595043].
Paasche-Orlow MK, Schillinger D, Green SM, Wagner EH. How healthcare systems can begin to address the challenge of limited literacy. Journal of General Internal Medicine. 2006;21(8):884-887. [pmid: 16881952].
Reardon KK, Rogers EM. Interpersonal versus mass media communication: A false dichotomy. Human Communication Research. 1988;15(2):284-303.
Rogers EM. 1983. Diffusion of innovations. 3rd ed. NY. The Free Press.
Rozenblit LR, Keil FC. The misunderstood limits of folkscience: An illusion of explanatory depth. Cognitive Science. 2002;26:521-562.
Rudd RE, Anderson JE. 2007. The Health Literacy Environment of Hospitals and Health Centers. Partners for Action: Making Your Healthcare Facility Literacy-Friendly. Cambridge, MA. National Center for the Study of Adult Learning and Literacy.
Rudd R, Kirsch IS, Yamamoto K. 2004. Literacy and Health in America. Princeton, NJ. Center for Global Assessment, Policy Information Center, Research and Development, Educational Testing Services.
Rudd RE, Soricone L, Santos M. 2006a. Health Literacy Study Circles+: Skills for Chronic Disease Management. Boston, MA. National Center for the Study of Adult Learning and Literacy.
Rudd RE, Soricone L, Santos M. 2006b. Health Literacy Study Circles+: Skills for Health Care Access and Navigation. Boston, MA. National Center for the Study of Adult Learning and Literacy.
Rudd RE, Soricone L, Santos M. 2007. Health Literacy Study Circles+: Skills for Disease Prevention and Screening. Boston, MA. National Center for the Study of Adult Learning and Literacy.
Saba G, Wong ST, Schillinger D, Fernandez A, Somkin CP, Wilson C, et al. Shared decision making and the experience of partnership in primary care. Annals of Family Medicine. 2006;4(1):54-62. [pmid: 16449397].
Schillinger D, Bindman A, Stewart A, Wang F, Piette J. Health literacy and the quality of physician-patient interpersonal communication. Patient Education and Counseling. 2004;3:315-323. [pmid: 14998602].
Schillinger D, Hammer H, Wang F. (in press). Seeing in 3-D: Examining the reach of diabetes self-management support strategies in a public healthcare system. Health Education and Behavior.
Schillinger D, Machtinger E, Wang F, Rodriguez M, Bindman A. The importance of establishing regimen concordance in preventing medication errors in anticoagulant care. Journal of Health Communication. 2006;11(6):555-67. [pmid: 16950728].
Schillinger D, Wang F, Grumbach K, Daher C, Palacios J, Diaz-Sullivan G, et al. Association of health literacy with diabetes outcomes. JAMA. 2002;288:475-482. [pmid: 12132978].
Sentell TL, Halpin HA. Importance of Adult Literacy in Understanding Health Disparities. Journal of General Internal Medicine. 2006;21(8):862-866. [pmid: 16881948].
Siegel M, Doner L. 1998. Marketing Public Health: Strategies to promote social change. Gaithersburg, MD. Aspen.
Sigelman CK, Rinehart CS, Sorongon AG, Bridges LJ, Wirtz PW. Teaching a coherent theory of drug action to elementary school children. Health Education Research. 2004;19:501-513. [pmid: 15150136].
Simons DJ, Keil FC. An abstract to concrete shift in the development of biological thought: The insides story. Cognition. 1995;56:129-163. [pmid: 7554792].
Skurnik I, Yoon C, Park D, Schwarz N. How warnings about false claims become recommendations. Journal of Consumer Research. 2005;31:713-734.
Sudore RL, et al. (in press). An advance directive redesigned to meet the literacy level of most adults: A randomized trial. Patient Education and Counseling.
Sudore RL, Landefeld CS, Williams B, Barnes D, Lindquist K, Schillinger D. Use of a modified informed consent process among vulnerable patients: A descriptive study. Journal of General Internal Medicine. 2006;21(8):867-873. [pmid: 16881949].
Sudore RL, Yaffe K, Satterfield S, Harris T, Mehta K, Simonsick E, et al. Limited literacy and mortality in the elderly: The health, aging, and body composition study. Journal of General Internal Medicine. 2006;21(8):806-812. [pmid: 16881938].
Taub HA, Baker MT, Sturr JF. Effects of readability, patient age, and education. Journal of the American Geriatrics Society. 1986;34:601-606. [pmid: 3722678].
Tichenor PJ, Donohu GA, Olien GN. Mass media flow and differential growth in knowledge. Public Opinion Quarterly. 1970;34(2):158-170.
Tichenor PJ, Donohue GA, Olien CN. 1980. Community conflict and the press. Newbury Park, CA. Sage.
United States Department of Health and Human Services, Office of Disease Prevention and Health Promotion. 2006a. Quick Guide to health literacy. Accessed 8/1/06. from http://www.health.gov/communication/literacy/quickguide/.
United States Departement of Health and Human Services, website on usability. 2006b. Accessed 8/25/06 from. http://www.usability.gov.
Vaiana ME, McGlynn EA. What cognitive science tells us about the design of reports for consumers. Medical Care Research and Review. 2002;59(1):3-35. [pmid: 11877877].
Weiss BD, Francis L, Senf JH, Heist K, Hargraves R. Literacy education as treatment for depression in patients with limited literacy and depression: A randomized controlled trial. Journal of General Internal Medicine. 2006;21(8):823-828. [pmid: 16881941].
Wolf MS, Gazmararian JA, Baker DW. Health literacy and functional health status among older adults. Archives of Internal Medicine. 2005;165(17):1946-1952. [pmid: 16186463].
Zarcadoolas C, Blanco M, Boyer JF. Unweaving the Web: An exploratory study of low-literate adults’ navigation skills on the World Wide Web. Journal of Health Communication. 2002;7(4):309-224. [pmid: 12356289].
Zarcadoolas C, Pleasant A, Greer DS. 2006. Advancing Health Literacy: A framework for understanding and action. San Francisco, CA. Jossey-Bass.