# Workshop Proceedings

This document summarizes the scientific research, views, and issues addressed by invited speakers and discussants at the Surgeon General’s Workshop on Improving Health Literacy. The speakers were selected because their research and experience have important health literacy applications.

In preparing their presentations, the speakers were asked to include broad health literacy implications, rather than to focus exclusively on individual research or studies. They were asked to address the following questions:

- What does your research suggest about the barriers to health literacy improvement;
- What does your research suggest about the types of changes that are needed;
- How does your research or study translate into action steps for health literacy improvement;
- Which sectors, organizations or groups should contribute to health literacy improvement?

The views expressed in these proceedings reflect the opinions of the individual participants at the Workshop and do not necessarily reflect the official position of the Office of the Surgeon General, the Department of Health and Human Services (DHHS), or other federal agencies.

## Welcome

RADM Penelope Slade Royall, P.T., M.S.W.,

Deputy Assistant Secretary for Disease Prevention and Health Promotion,

Office of Disease Prevention and Health Promotion,

U.S. Department of Health and Human Services

The Surgeon General’s Workshop on Improving Health Literacy was called to order on September 7, 2006 by Rear Admiral (RADM) Penelope Slade Royall. RADM Royall welcomed participants and spoke of the challenges of the day’s Workshop—to review the large body of scientific evidence in support of health literacy improvement and to identify gaps in information that need to be assigned priorities. RADM Royall then introduced the Acting Surgeon General, RADM Kenneth P. Moritsugu, who reviewed the charge and goals for the Workshop.

## Charge and Goals

RADM Kenneth P. Moritsugu, M.D., M.P.H.,

Acting U.S. Surgeon General

RADM Moritsugu emphasized the important role health literacy plays in efforts to improve the public’s health. When people have accurate, understandable information about a public health issue, they are better able to take action to maintain or improve their health. The Office of the Surgeon General focuses on three major health priorities: prevention, public health preparedness, and eliminating health disparities. Health literacy is a critical underpinning to each of these priorities.

### Definition of Health Literacy

RADM Moritsugu began with the definition of health literacy first developed in the National Library of Medicine bibliography on health literacy and adopted by Healthy People 2010 and the Institute of Medicine (IOM). Health literacy is the degree to which individuals have the capacity to obtain, process, and understand basic health information and services needed to make appropriate health decisions. The 2004 IOM report, Health Literacy: A Prescription to End Confusion, builds on this definition and conceptualizes health literacy as a shared function of cultural, social, and individual factors. According to the report, both the causes and remedies of limited health literacy rest with our cultural and social frameworks, the health and education systems that serve them, and the interactions between these factors and individuals.

### Limited Health Literacy: A Public Health Problem

Health literacy is the degree to which individuals have the capacity to obtain, process, and understand basic health information and services needed to make appropriate health decisions.

Healthy People 2010

The Acting Surgeon General encouraged those in attendance to challenge their assumptions about health literacy research and practice. He urged participants to look at health literacy from every angle—from the perspectives of health professionals and those they serve. People of all ages, races, incomes, and education levels are affected by limited health literacy. Even the seemingly simple things that we can all do to stay healthy and safe, such as getting recommended screenings and eating healthy foods, can be difficult for some people. The reality is that to be able to make healthy choices, people must have a basic understanding of how to find and use health information. And they must also understand why these choices are important.

Several recent events have drawn attention to the challenge of limited health literacy. In early 2000, Healthy People 2010 identified limited health literacy as a public health problem and set national objectives for its improvement. In 2004, the IOM released its health literacy report, finding that nearly one-half of American adults may lack the needed literacy skills to use the U.S. health care system. At the same time, the Agency for Health Care Research and Quality (AHRQ) released its evidence report on literacy and health outcomes (Berkman, et al., 2004). This report was the result of a thorough scientific review of the evidence related to the effect of low literacy on a wide variety of health outcomes.

### A Public Health Approach to Health Literacy Improvement

RADM Moritsugu emphasized the importance of taking a public health approach to health literacy improvement. He noted that over the past 100 years, thanks largely to public health efforts, we have successfully prevented the spread of infectious diseases, increased the life expectancy of Americans, protected against environmental hazards, and reduced accidents and injuries. As threats to America’s health shift, so too do our public health efforts. The public health approach allows us to address new challenges such as limited health literacy by defining the problem; identifying its causes and protective factors; developing and testing intervention strategies; implementing interventions; and evaluating and refining those interventions.

### Goals for the Workshop

RADM Moritsugu presented the three major goals for the workshop:

- Identify the latest scientific data on the scope and public health consequences of limited health literacy.
- Review and discuss the research needs and identify areas where information is lacking.
- Based on the body of health literacy research, establish an evidence base for taking steps to improve health literacy.

The purpose of the meeting is to present a critical analysis and understanding of the state of the science in the field of health literacy. He emphasized that this workshop is not the end point, but rather, the beginning of a series of activities that the Office of the Surgeon General is undertaking to move this issue forward.

## Moderator Opening Remarks

William Smith, Ed.D.,

Executive Vice President,

Academy for Education Development

William Smith, Ed.D., Executive Vice President, Academy for Educational Development Dr. Smith, a member of the IOM Committee on Health Literacy, described health literacy as a cultural phenomenon. In order to be a truly health literate society, we have to be aware of how culture shapes our understanding of health. We are accustomed to thinking of health literacy as an individual competency or deficit, and asking the question, is she or he literate? But a more appropriate question is, are we a health literate nation?

He reminded attendees that there are thousands of professionals and educators who are working hard to improve the health literacy of adults, and he urged participants to help those in the field evaluate their efforts.

The day’s presentations address the scope and the public health consequences of limited health literacy. Dr. Smith noted that the research presented at the workshop has already been through rigorous scientific review. Participants’ job is not to analyze the validity of the results but rather the relevance of the conclusions and their implications for public health practice.