# Acknowledgements

## Surgeon General’s Workshop on Improving Health Literacy

The Surgeon General’s Workshop on Improving Health Literacy was co-sponsored by the Office of the Surgeon General and the Office of Disease Prevention and Health Promotion.

The Acting Surgeon General and the Deputy Assistant Secretary for Disease Prevention and Health Promotion expresses their sincere appreciation to all who contributed time, experience, and knowledge to support the development of the Surgeon General’s Workshop on Improving Health Literacy and this report. The Acting Surgeon General and the Deputy Assistant Secretary for Disease Prevention and Health Promotion would especially like to acknowledge the following:

### HHS Health Literacy Workgroup

The Department of Health and Human Services (HHS) Health Literacy Workgroup was formed in 2004 under the leadership of the Office of Disease Prevention and Health Promotion. The Workgroup fosters inter-agency collaboration to raise awareness of this issue, meeting bi-monthly to review progress, share information, and develop strategic plans and activities on health literacy. Members of the Workgroup formed a Steering Committee to develop a Surgeon General’s Workshop on Improving Health Literacy. Their commitment to improve the health literacy of all Americans led to a robust presentation of the science and research base that supports the improvement of health literacy.

### Workshop Attendees

Approximately 80 experts in the field of health literacy and related disciplines attended the invitation-only Surgeon General’s Workshop on Improving Health Literacy. The participants provided valuable insights concerning the scope of the problem of limited health literacy, highlighting gaps in the knowledge base, and suggesting methods to improve health literacy. Their thoughtful contributions helped guide the development of this report.

### Government Agencies

The Surgeon General’s Workshop on Improving Health Literacy was sponsored by the following HHS Agencies and Offices:

- Agency for Healthcare Research and Quality
- Administration on Aging
- Centers for Disease Control and Prevention
- Food and Drug Administration
- Indian Health Service
- Office of HIV/AIDS Policy
- Office of Minority Health
- Substance Abuse and Mental Health Services Administration
- National Institutes of Health
  - – National Cancer Institute
  - – National Eye Institute
  - – National Human Genome Research Institute
  - – National Heart, Lung and Blood Institute
  - – National Institute of Dental and Craniofacial Research
  - – National Institute of Child Health and Human Development
  - – National Institute on Drug Abuse
  - – National Library of Medicine
  - – Office of Communications and Public Liaison
  - – Office of Disease Prevention

### Health Literacy Workshop Steering Committee

The Acting Surgeon General and the Deputy Assistant Secretary for Disease Prevention and Health Promotion would especially like to recognize the following individuals for their assistance in organizing the workshop and preparing this report.

- Workshop Coordinator
- Cynthia Baur
- Proceedings Author
- Stacy Robison

- Group Members
  - Office of the Surgeon General
  - Mary Beth Bigley
  - CDR Karen Near
  - Ron Schoenfeld
  - RADM Robert Williams
  - Office of Disease Prevention and Health Promotion
  - Alice Horowitz
  - Joanne Locke
  - CAPT David Rutstein
  - HHS Agencies and Offices
  - Lisa Adams
  - Neyal Ammary
  - Peter Bonner
  - Daniel Berch
  - Cindy Brach
  - Martin Dannenfelser
  - Elizabeth Goldstein
  - Sarah Gregory
  - Sandra Hilfiker
  - Megan Homer
  - Kimberly Kaphingst
  - Pamela Kelley
  - Jennifer Klocinski
  - Camha Le
  - Robert Logan
  - Carmela Lomonaco
  - Sheryl Massaro
  - Charlotte Neuhaus
  - Victor Olano
  - Nancy Ostrove
  - Guadalupe Pacheco
  - Toni Stifano
  - Martina Vogel-Taylor
  - Mary Wachacha
  - Maria White
  - Violet Woo
  - Sabra Woolley