# Participant List

## Surgeon General’s Workshop on Improving Health Literacy

- Marin P. Allen, Ph.D.
- Deputy Associate Director for Communications and Public Liaison and Director of Public Information
- Office of the Director
- National Institutes of Health
- U.S. Department of Health and Human Services
- Building 1, Room 344
- 1 Center Drive
- Bethesda, MD 20892
- Phone: (301) 496-5787
- Fax: (301) 496-0017
- E-mail: allenma@od.nih.gov

- Wilma Alvarado-Little, M.A.
- Program Manager
- Center for the Elimination of Minority Health Disparities
- University at Albany, SUNY
- AS 236
- 1400 Washington Avenue
- Albany, NY 12222
- Phone: (518) 442-5976
- Fax: (518) 442-4563
- E-mail: walittle@albany.edu

- Neyal J. Ammary, M.P.H., C.H.E.S.
- Assistant Director, National Eye Health Education Program
- National Eye Institute
- National Institutes of Health
- U.S. Department of Health and Human Services
- Building 31, Room 6A32
- 31 Center Drive, MSC 2510
- Bethesda, MD 20892
- Phone: (301) 496-3072
- Fax: (301) 402-1065
- E-mail: ammaryn@nei.nih.gov

- David W. Baker, M.D., M.P.H., F.A.C.P.
- Chief, Division of General Internal Medicine
- Feinberg School of Medicine
- Northwestern University
- 676 North St. Clair
- Chicago IL, 60611
- Phone: (312) 695-0917
- Fax: (312) 695-4307
- E-mail: dwbaker@northwestern.edu

- Sharon E. Barrett, M.S.
- Consultant
- Association of Clinicians for the Underserved
- 10534 Green Mountain Circle
- Columbia, MD 21044
- Phone: (410) 992-1819
- Fax: (410) 997-8864
- E-mail: semily1@msn.com

- Cynthia Baur, Ph.D.
- Senior Health Communication and e-Health Advisor
- Office of Disease Prevention and Health Promotion
- U.S. Department of Health and Human Services
- 1101 Wootton Parkway, Suite LL100
- Rockville, MD 20852
- Phone: (240) 453-8262
- Fax: (240) 453-8281
- E-mail: cynthia.baur@hhs.gov

- Sandra L. Baxter, Ed.D.
- Director
- National Institute for Literacy
- 1775 I Street, N.W., Suite 730
- Washington, DC 20006-2401
- Phone: (202) 233-2025
- Fax: (202) 233-2050
- E-mail: sbaxter@nifl.gov

- Daniel B. Berch, Ph.D.
- Associate Chief, Child Development and Behavior Branch
- National Institute of Child Health and Human Development
- National Institutes of Health
- U.S. Department of Health and Human Services
- 6100 Executive Boulevard, Room 4B05
- Bethesda, MD 20892-7510
- Phone: (301) 402-0699
- Fax: (301) 480-0230
- E-mail: berchd2@mail.nih.gov

- Mary Beth Bigley, Dr.P.H., M.S.N., A.N.P.
- Senior Health Fellow
- Office of the Surgeon General
- U.S. Public Health Service
- U.S. Department of Health and Human Services
- Parklawn Building, Room 18–55
- 5600 Fishers Lane
- Rockville, MD 20857
- Phone: (301) 443-4000
- Fax: (301) 443-1202
- E-mail: marybeth.bigley@hhs.gov

- Anita B. Boles
- Executive Director
- Partnership for Clear Health Communication
- 1615 L Street N.W., Suite 1000
- Washington, DC 20036-5610
- Phone: (202) 203-8738
- Fax: (202) 296-3977
- E-mail: aboles@p4chc.org

- Cindy Brach
- Agency for Health Research and Quality
- U.S. Department of Health and Human Services
- 540 Gaither Road
- Rockville, MD 20850
- Phone: (301) 427-1444
- Fax: (301) 427-1430
- E-mail: cbrach@ahrq.gov

- Cecelia Butler, M.S., R.D., C.D.E.
- Registered Dietician
- Santa Fe Indian Hospital
- 1700 Cerrillos Road
- Santa Fe, NM 87501
- Phone: (505) 946-9390
- Fax: (505) 983-6243
- E-mail: cecelia.butler@ihs.gov

- Dana S. Carr, M.P.H.
- Program Specialist
- Office of Safe and Drug-Free Schools
- U.S. Department of Education
- 400 Maryland Avenue, S.W. FB-6
- Washington, DC 20202-6450
- Phone: (202) 260-0823
- Fax: (202) 260-7767
- E-mail: dana.carr@ed.gov

- Martin J. Dannenfelser, Jr.
- Senior Advisor to the Assistant Secretary
- Administration for Children and Families
- U.S. Department of Health and Human Services
- 370 L’Enfant Promenade, S.W.
- Suite 600 West
- Washington, DC 20447
- Phone: (202) 401-6947
- Fax: (202) 260-4524
- E-mail: martin.dannenfelser@acf.hhs.gov

- Barbara DeBuono, M.D., M.P.H.
- Senior Medical Advisor, Public Health
- Pfizer Pharmaceuticals, Inc.
- 235 East 42nd Street, 205/4/7
- New York, NY 10017
- Phone: (212) 733-5185
- E-mail: barbara.debuono@pfizer.com

- Timothy E. D’Emilio
- Research Analyst
- Office of English Language Acquisition
- U.S. Department of Education
- Potomac Center Plaza, Room 10102
- 550 12th Street, S.W.
- Washington, DC 20065
- Phone: (202) 245-7144
- Fax: (202) 245-7163
- E-mail: tim.d’emilio@ed.gov

- Dogan Eroglu, Ph.D., M.P.H.
- Acting Deputy Director
- National Center for Health Marketing
- Coordinating Center for Health Information and Service
- Centers for Disease Control and Prevention
- U.S. Department of Health and Human Services
- 1600 Clifton Road, N.E., MS E-21
- Atlanta, GA 30329
- Phone: (404) 498-0990
- Fax: (404) 498-2221
- E-mail: dogan.eroglu@cdc.hhs.gov

- Caswell A. Evans, Jr., D.D.S., M.P.H.
- Associate Dean for Prevention and Public Health Sciences
- College of Dentistry
- University of Illinois at Chicago
- 801 South Paulina Street
- Chicago, IL 60612
- Phone: (312) 413-7365
- Fax: (312) 413-9050
- E-mail: casevans@uic.edu

- Glenn D. Flores, M.D., F.A.A.P.
- Director, Center for the Advancement of Underserved Children
- Professor (with tenure) of Pediatrics, Epidemiology & Health Policy
- Medical College of Wisconsin and Children’s Hospital of Wisconsin
- 8701 Watertown Plank Road, CCN 2nd Floor
- Milwaukee, WI 53206-0509
- Phone: (414) 456-8273
- Fax: (414) 456-6385
- E-mail: agflores@mcw.edu

- Sheila Foran, J.D.
- Acting Deputy Director, Civil Rights
- Office for Civil Rights
- U.S. Department of Health and Human Services
- 200 Independence Avenue, S.W., Room 515-F
- Washington, DC 20201
- Phone: (202) 619-1002
- Fax: (202) 619-3437
- E-mail: sheila.foran@hhs.gov

- Harold P. Freeman, M.D.
- President, Founder, and Medical Director
- Ralph Lauren Center for Cancer Care and Prevention
- 1919 Madison Avenue
- New York, NY 11035
- Phone: (212) 987-1777
- Fax: (212) 987-1776
- E-mail: hfreeman@mail.nih.gov

- Vicki S. Freimuth, Ph.D.
- Professor
- University of Georgia
- 0134 Terrell Hall
- Athens, GA 30602
- Phone: (706) 542-0586
- E-mail: freimuth@uga.edu

- Denise H. Geolot, Ph.D., R.N., F.A.A.N.
- Director, Center for Quality
- Health Resources and Services Administration
- U.S. Department of Health and Human Services
- Parklawn Building, Room 7-100
- 5600 Fishers Lane
- Rockville, MD 20857
- Phone: (301) 443-0458
- Fax: (301) 443-9795
- E-mail: dgeolot@hrsa.gov

- Robert S. Gold, Ph.D., Dr.P.H., F.A.A.H.B.
- Dean, College of Health & Human Performance
- University of Maryland
- 3310 D HHP Building, #255
- College Park, MD 20742-2611
- Phone: (301) 405-2437
- Fax: (301) 405-8397
- E-mail: rsgold@umd.edu

- Sarah Gregory
- Health Communications Specialist
- National Center for Health Marketing
- Centers for Disease Control and Prevention
- U.S. Department of Health and Human Services
- 1600 Clifton Road, Mailstop E-69
- Atlanta, GA 30329
- Phone: (404) 498-0960
- Fax: (404) 498-0988
- E-mail: sarah.gregory@cdc.hhs.gov

- Mary Guthrie
- Acting Director
- Center for Planning and Policy
- U.S. Administration on Aging
- One Massachusetts Avenue, N.W
- Washington, D.C 20001
- Phone: (202) 357-3443
- E-mail: mary.guthrie@aoa.hhs.gov

- Dena L. Hasan
- Research Analyst
- Division of Beneficiary Analysis
- Centers for Medicare and Medicaid Services
- U.S. Department of Health and Human Services
- S1-13-01
- 7500 Security Boulevard
- Baltimore, MD 21244
- Phone: (410) 786-1820
- Fax: (410) 786-8004
- E-mail: dena.williams1@cms.hhs.gov

- Judith Hibbard, Dr.P.H.
- Professor
- Department of Planning, Public Policy, and Management
- University of Oregon
- 119 Hendricks Hall
- Eugene, OR 97403-1209
- Phone: (541) 346-3364
- Fax: (541) 346-2040
- E-mail: jhibbard@uoregon.edu

- Sandra Williams Hilfiker, M.A.
- Public Health Advisor
- Office of Disease Prevention and Health Promotion
- U.S. Department of Health and Human Services
- 1101 Wootton Parkway, Suite LL100
- Rockville, MD 20852
- Phone: (240) 453-8268
- Fax: (301) 453-8281
- E-mail: sandraw.hilfiker@hhs.gov

- Megan Homer
- Centers for Medicare and Medicaid Services
- 7500 Security Blvd, Mailstop: C4-10-07
- Baltimore, MD 21244-1850
- Phone: (410) 786-9513
- Fax: (410) 786-0330
- Email: megan.homer@cms.hhs.gov

- Alice M. Horowitz, Ph.D.
- Education Specialist
- National Institute of Dental and Craniofacial Research
- National Institutes of Health
- U.S. Department of Health and Human Services
- 45 Center Drive, Room 4AS-37A
- Bethesda, MD 20892-6401
- Phone: (301) 594-5391
- Fax: (301) 480-8254
- E-mail: alice.horowitz@nih.gov

- Betsy Humphreys
- Deputy Director
- National Library of Medicine
- National Institutes of Health
- U.S. Department of Health and Human Services
- 38 Center Drive, Room 2E17A
- MSSC 3809
- Bethesda, MD 20892
- Phone: (301) 496-6661
- Fax: (301) 496-4450
- E-mail: betsy_humphreys@nlm.nih.gov

- CAPT Candace Jones, R.D.H., M.P.H.
- Acting Deputy Director
- Office of Clinical and Preventive Services
- Indian Health Service
- U.S. Department of Health and Human Services
- 801 Thompson Avenue, Suite 310
- Rockville, MD 20852
- Phone: (301) 443-4330
- Fax: (301) 594-6213
- E-mail: candace.jones@ihs.hhs.gov

- Cheryl Keenan
- Director
- Division of Adult Education and Literacy
- Office of Vocational and Adult Education
- U.S. Department of Education
- Potomac Center Plaza
- 550 12th Street, S.W., Room 11151
- Washington, DC 20202-7240
- Phone: (202) 245-7810
- Fax: (202) 245-7171
- E-mail: cheryl.keenan@ed.gov

- Frank C. Keil, Ph.D.
- Professor of Psychology and Linguistics
- Department of Psychology
- Yale University
- P.O. Box 208205
- New Haven, CT 06520
- Phone: (203) 432-2389
- Fax: (203) 432-7172
- E-mail: frank.keil@yale.edu

- Dushanka Kleinman, D.D.S.
- Deputy Director
- National Institute of Dental and Craniofacial Research
- National Institutes of Health
- U.S. Department of Health and Human Services
- Building 31, Room 2C39
- 31 Center Drive, MSC2290
- Bethesda, MD 20892
- Phone: (301) 496-9469
- Fax: (301) 402-2185
- E-mail: dushanka.kleinman@nih.hhs.gov

- Jennifer Klocinski, M.A.
- Aging Services Program Specialist
- Office for Community Based Services
- Center for Wellness and Community Based Services
- Administration on Aging
- U.S. Department of Health and Human Services
- 1 Massachusetts Avenue, N.W.
- Room 5402
- Washington, DC 20201
- Phone: (202) 357-0146
- Fax: (202) 357-3549
- E-mail: jennifer.klocinski@aoa.hhs.gov

- Andrew Kolstad
- Senior Technical Advisor to the Assessment Division
- National Center for Education Statistics
- U.S. Department of Education
- 1990 K Street, N.W., Cubical 8087
- Washington, DC 20006
- Phone: (202) 502-7374
- Fax: (202) 502-7440
- E-mail: andrew.kolstad@ed.gov

- Jean A. Krause
- Executive Vice President and CEO
- American College of Physicians Foundation
- 190 North Independence Mall West
- Philadelphia, PA 19106-15723
- Phone: (215) 351-2807
- Fax: (215) 351-2612
- E-mail: jkrause@acponline.org

- Mark Kutner, Ph.D.
- Deputy Director
- Pelavin Research Center
- American Institutes for Research
- 1000 Thomas Jefferson Street, N.W.
- Washington, DC 20007
- Phone: (202) 403-5321
- Fax: (202) 403-5408
- E-mail: mkutner@air.org

- Camha T. Le, M.S.
- Public Health Analyst
- Emerging Leaders Program
- Office for the Advancement of Telehealth
- Office of Health Information Technology
- Health Resources and Services Administration
- U.S. Department of Health and Human Services
- Parklawn Building, Room 7C-22
- 5600 Fishers Lane
- Rockville, MD 20857
- Tel: (301) 443-2919
- Fax: (301) 443-1330
- Email: cle@hrsa.gov

- Robert C. Like, M.D., M.S.
- Professor and Director
- Center for Healthy Families and Cultural Diversity
- Department of Family Medicine
- UMDNJ-Robert Wood Johnson Medical School
- 1 Robert Wood Johnson Place
- New Brunswick, NJ 08903
- Phone: (732) 235-7662
- Fax: (732) 246-8084
- E-mail: like@umdnj.edu

- Joanne Locke, M.A.S.
- Plain Language Advisor
- Office of Disease Prevention and Health Promotion
- U.S. Department of Health and Human Services
- 1101 Wootton Parkway, Suite LL100
- Rockville, MD 20852
- Phone: (240) 453-6113
- Fax: (240) 453-8281
- E-mail: joanne.locke@hhs.gov

- Robert A. Logan, Ph.D.
- Lister Hill National Center for Biomedical Communications
- National Library of Medicine
- National Institutes of Health
- U.S. Department of Health and Human Services
- Building 38A, Room 7S720
- 8600 Rockville Pike
- Bethesda, MD 20894
- Phone: (301) 496-1936
- Fax: (301) 402-0118
- E-mail: robert_logan@nlm.nih.gov

- Yvonne Maddox, Ph.D.
- Deputy Director
- National Institute of Child Health and Human Development
- National Institutes of Health
- U.S. Department of Health and Human Services
- 31 Center Drive, Room 2A03, MSC 2425
- Bethesda, MD 20892-2425
- Phone: (301) 496-1848
- Fax: (301) 402-1104
- E-mail: yvonne.maddox@nih.hhs.gov

- Rose Marie Martinez, Sc.D.
- Director
- Board on Population Health and Public Health Practice
- Institute of Medicine
- 500 Fifth Street, N.W.
- Washington, DC 20001
- Phone: (202) 334-2655
- Fax: (202) 334-1412
- E-mail: rmartinez@nas.edu

- Russell P. Massaro, M.D., F.A.C.P.E.
- Executive Vice President
- Accreditation and Certification Operations
- Joint Commission on Accreditation of Healthcare Organizations
- One Renaissance Boulevard
- Oakbrook Terrace, IL 60181
- Phone: (630) 792-5750
- Fax: (630) 792-4750
- E-mail: rmassaro@jcaho.org

- Sheryl Massaro
- Team Leader, Special Projects
- National Institute on Drug Abuse
- National Institutes of Health
- U.S. Department of Health and Human Services
- 6001 Executive Boulevard, Room 5201
- Rockville, MD 20852
- Phone: (301) 594-6146
- Fax: (301) 443-7397
- E-mail: smassaro@ngmsmtp.nida.nih.gov

- Lauren McCormack, Ph.D., M.S.P.H.
- Director, Health Communication Program
- RTI International
- 3040 Cornwallis Road
- P.O. Box 12194
- Research Triangle Park, NC 27709-2194
- Phone: (919) 541-6277
- Fax: (919) 990-8454
- E-mail: lmac@rti.org

- M. Valerie Mills, Ph.D., M.S.W.
- Senior Health Policy Advisor
- Substance Abuse and Mental Health Services Administration
- U.S. Department of Health and Human Services
- 1 Choke Cherry Road, Room 8007
- Rockville MD 20857
- Phone: (240) 276-2232
- Fax: (240) 276-2251
- E-mail: valerie.mills@samhsa.hhs.gov

- RADM Kenneth P. Moritsugu, M.D., M.P.H.
- Acting Surgeon General
- U.S. Public Health Service
- U.S. Department of Health and Human Services
- Parklawn Building, Room 18-67
- 5600 Fishers Lane
- Rockville, MD 20857
- Phone: (301) 443-4000
- Fax: (301) 443-3590
- E-mail: kenneth.moritsugu@hhs.gov

- Gregory Morosco, Ph.D.
- Associate Director for Prevention, Education, and Control
- National Heart, Lung, and Blood Institute
- National Institutes of Health
- U.S. Department of Health and Human Services
- Building 31, Room 4A10
- 31 Center Drive
- Bethesda, MD 20892
- Phone: (301) 496-5437
- Fax: (301) 480-4907
- E-mail: moroscog@nhlbi.nih.gov

- Andres Muro, M.A.
- Manager, Community Education Program
- El Paso Community College
- OR Center
- Building 4050, Room 145
- P.O. Box 20500
- El Paso, TX 79998
- Phone: (915) 831-4161
- Fax: (915) 841-4161
- E-mail: andresm@epcc.edu

- CDR Karen Near, M.D., M.S.
- Senior Science Advisor, Office of the Surgeon General
- U.S. Public Health Service
- U.S. Department of Health and Human Services
- Parklawn Building, Room 18C-14
- 5600 Fishers Lane
- Rockville, MD 20857
- Phone: (301) 443-4000
- Fax: (301) 443-3574
- E-mail: karen.near@hhs.gov

- Linda Neuhauser, Dr.P.H.
- Clinical Professor
- Community Health and Human Development
- School of Public Health
- University of California
- 140 Warren Hall MC 7360
- Berkeley, CA 94720-7360
- Phone: (510) 643-9177
- Fax: (510) 642-9792
- E-mail: lindan@berkeley.edu

- Victor Olano, M.P.H.
- Community Health Specialist
- Office of Prevention, Education, and Control
- National Heart, Lung, and Blood Institute
- National Institutes of Health
- U.S. Department of Health and Human Services
- Building 31, Room 4A10
- 31 Center Drive
- Bethesda, MD 20892
- Phone: (301) 496-1051
- Fax: (301) 402-1051
- E-mail: olanov@nhlbi.nih.gov

- Nancy M. Ostrove, Ph.D.
- Senior Advisor for Risk Communication
- Food and Drug Administration
- U.S. Department of Health and Human Services
- Parklawn Building, Room 14-101, HFP-1
- 5600 Fishers Lane
- Rockville, MD 20857
- Phone: (301) 827-9279
- Fax: (301) 594-6777
- E-mail: nancy.ostrove@fda.hhs.gov

- Guadalupe Pacheco
- Special Assistant to the Director
- Office of Minority Health
- U.S. Department of Health and Human Services
- 1101 Wootton Parkway, Suite 600
- Rockville, MD 20852
- Phone: (240) 453-6174
- Fax: (301) 597-0767
- E-mail: guadalupe.pacheco@hhs.gov

- Denise Park, Ph.D.
- Director, Roybal Center
- University of Illinois at Urbana-Champaign
- 509 Psychology Building
- 603 East Daniel Street
- Champaign, IL 61820
- Phone: (217) 333-7647
- Fax: (217) 244-5876
- E-mail: denisep@uiuc.edu

- Sylvia Park, M.D., M.P.H.
- Bloomberg School of Public Health
- Johns Hopkins University
- 615 North Wolfe Street, Room WB-602
- Baltimore, MD 21205
- Phone: (202) 841-2208
- Fax: (410) 614-1582
- E-mail: sypark@jhsph.edu

- Yolanda Partida, M.S.W., D.P.A.
- Director, National Program Office
- Hablamos Juntos II Language Policy and Practice in Health Care
- USCF Fresno
- Center for Medical and Education Research
- 155 North Fresno Street, Suite 266
- Fresno, CA 93701
- Phone: (559) 499-6406
- Fax: (559) 499-6693
- E-mail 1: ypartida@partidagroup.com
- E-mail 2: yolanda@hablamosjuntos.org

- Michael Pignone, M.D., M.P.H.
- Associate Professor of Medicine
- Division of General Medicine and Epidemiology
- University of North Carolina School of Medicine
- 5039 Old Clinic Building
- Campus Box #7110
- Chapel Hill, NC 27599-7110
- Phone: (919) 966-2276
- Fax: (919) 966-2274
- E-mail: pignone@med.unc.edu

- Lupita Reyes
- National Program Director
- Domestic Violence & Healthcare
- Verizon Foundation
- 295 N. Maple Avenue
- Basking Ridge, NJ 07920
- Phone: (908) 559-6373
- Fax: (908) 630-2660
- E-mail: lupita.reyes@verizon.com

- Stacy E. Robison, M.P.H.
- Health Literacy Fellow
- Office of Disease Prevention and Health Promotion
- U.S. Department of Health and Human Services
- 1101 Wootton Parkway, Suite LL100
- Rockville, MD 20852
- Phone: (240) 453-8271
- Fax: (240) 453-8281
- E-mail: stacy.robison@hhs.gov

- RADM Penelope Slade Royall, P.T., M.S.W.
- Deputy Assistant Secretary for Health
- U.S. Public Health Service
- Office of Disease Prevention and Health Promotion
- U.S. Department of Health and Human Services
- 1101 Wootton Parkway, Suite LL100
- Rockville, MD 20852
- Phone: (240) 453-8280
- Fax: (240) 453-8282
- E-mail: penelope.royall@hhs.gov

- Rima Rudd, Sc.D.
- Senior Lecturer of Society, Human Development and Health in the Faculty of Public Health
- Harvard School of Public Health
- Building 3, Room 719
- 677 Huntington Avenue
- Boston MA 02115
- Phone: (617) 432-1135
- Fax: (617) 432 3123
- E-mail: rrudd@hsph.harvard.edu

- CAPT David Rutstein
- Chief Medical Officer
- U.S. Public Health Service
- Deputy Director, Office of Disease Prevention and Health Promotion
- U.S. Department of Health and Human Services
- 1101 Wootton Parkway, Suite LL100
- Rockville, MD 20852
- Phone: (240) 453-8278
- Fax: (240) 453-8282
- E-mail: david.rutstein@hhs.gov

- Kurt Sackerman
- Senior Program Officer
- National Hispanic Medical Association
- 1411 K Street, N.W., Suite 1100
- Washington, DC 20005
- Phone: (202) 628-5895
- Fax: (202) 628-5898
- E-mail: ksackerman@nhmamd.org

- Dean Schillinger, M.D.
- Associate Professor of Clinical Medicine
- University of California San Francisco
- Division of General Internal Medicine
- San Francisco General Hospital
- Building 10, 3rd Floor
- 1001 Potrero Avenue
- San Francisco, CA 94110
- Phone: (415) 206-8940
- Fax: (415) 206-5586
- E-mail: dean@itsa.ucsf.edu

- Ron Schoenfeld, Ph.D.
- Senior Science Advisor
- Office of the Surgeon General
- U.S. Public Health Service
- U.S. Department of Health and Human Services
- Parklawn Building, Room 18-66
- 5600 Fishers Lane
- Rockville, MD 20857
- Phone: (301) 443-4000
- Fax: (301) 443-3574
- E-mail: ron.schoenfeld@hhs.gov

- Joanne G. Schwartzberg, M.D.
- Director, Aging and Community Health
- American Medical Association
- 515 North State Street
- Chicago, IL 60610
- Phone: (312) 464-5355
- Fax: (312) 464-5841
- E-mail: joanne.schwartzberg@ama-assn.org

- Harold Slavkin, D.D.S.
- Dean
- USC School of Dentistry
- 925 West 34th Street, Suite 203
- Los Angeles, CA 90089
- Phone: (213) 740-8095
- Fax: (213) 740-1509
- E-mail: slavkin@usc.edu

- William A. Smith, Ed.D.
- Executive Vice President
- Academy for Educational Development
- 1825 Connecticut Avenue, N.W.
- Washington, DC 20009-5721
- Phone: (202) 884-8750
- Fax: (202) 884-8400
- E-mail: bsmith@aed.org

- Toni M. Stifano
- Health Literacy Advisor
- Food and Drug Administration
- U.S. Department of Health and Human Services
- Parklawn Building, Room 15-62
- 5600 Fishers Lane
- Rockville, MD 20857
- Phone: (301) 827-2647
- Fax: (301) 827-5225
- E-mail: toni.stifano@fda.hhs.gov

- Martina Vogel-Taylor
- Senior Advisor for Disease Prevention
- Office of Disease Prevention
- Office of the Director
- National Institutes of Health
- U.S. Department of Health and Human Services
- 6100 Executive Boulevard, Suite 2B-03
- Bethesda, MD 20892-7523
- Phone: (301) 496-6614
- Fax: (301) 480-7660
- E-mail: mv18x@nih.gov

- Mary Wachacha
- Lead Consultant, Health Education
- Indian Health Service
- U.S. Department of Health and Human Services
- P.O. Box 752
- Cherokee, NC 28719
- Phone: (828) 292-1175
- Fax: (828) 497-5343
- E-mail: mary.wachacha@ihs.hhs.gov

- Maria E. White
- Office of Civil Rights
- Health Resources and Services Administration
- U.S. Department of Health and Human Services
- Parklawn Building, Room 6-105
- 5600 Fishers Lane
- Rockville, MD 20857
- Phone: (301) 443-0363
- Fax: (301) 443-7898
- E-mail: maria.white@hrsa.hhs.gov

- Grover (Russ) Whitehurst, Ph.D.
- Director, Institute of Education Sciences
- U.S. Department of Education
- 555 New Jersey Avenue, N.W.
- Room 600-D
- Washington, DC 20208
- Phone: (202) 219-0644
- Fax: (202) 219-1402
- E-mail: grover.whitehurst@ed.gov

- RADM Robert C. Williams
- Chief of Staff
- Office of the Surgeon General
- U.S. Public Health Service
- U.S. Department of Health and Human Services
- Parklawn Building, Room 18-55
- 5600 Fishers Lane
- Rockville, MD 20857
- Phone: (301) 443-4000
- Fax: (301) 443-1202
- E-mail: robert.williams@hhs.gov

- Susan F. Wooley, Ph.D., C.H.E.S.
- Executive Director
- American School Health Association
- 7263 State Route 43
- P.O. Box 708
- Kent, Ohio 44240
- Phone: (330) 678-1601
- Fax: (330) 678-4526
- E-mail: swooley@ashaweb.org

- Sabra F. Woolley, Ph.D.
- Program Manager
- Health Communication and Informatics Branch
- Behavioral Research Program
- Division of Cancer Control and Population Sciences
- National Cancer Institute
- National Institutes of Health
- U.S. Department of Health and Human Services
- 6130 Executive Boulevard, Room 4078
- Bethesda, MD 20892
- Phone: (301) 435-4589
- Fax: (301) 480-6637
- E-mail: woolleys@mail.nih.gov

- Christina Zarcadoolas, Ph.D.
- Associate Clinical Professor
- Community and Preventative Medicine
- Health and Environmental Literacy
- Department of Community and Preventive Medicine
- Mt. Sinai School of Medicine
- Box 1043
- One Gustave Levy Place
- New York, NY 10029
- Phone: (212) 241-0625
- E-mail: christina.zarcadoolas@mssm.edu