# Comparing Thiazolidinediones

The most common type of diabetes is type 2. High blood sugar levels are initially caused by the body becoming resistant to the effects of insulin, but over time, the body produces less insulin. Type 2 diabetes is managed with changes to diet and lifestyle, and often medications are used to lower blood sugar. These medications include oral drugs such as the thiazolidinediones.

Thiazolidinediones lower glucose levels in a number of ways. They reduce the amount of glucose the body makes, increase the rate at which glucose is broken down, make the body more sensitive to insulin and also have a beneficial effect on the beta cells that make insulin. Currently rosiglitazone and pioglitazone are the only thiazolidinediones licensed in the U.S. to treat type 2 diabetes.

The "Drug Class Review on Thiazolidinediones" compares the safety and effectiveness of two drugs. A summary of the findings is below.

## How do thiazolidinediones compare in lowering blood sugar levels?

HbA1c (glycated hemoglobin) is a marker of long-term blood glucose control. A high level of HbA1c indicates poor control of diabetes over the previous 2 to 3 months.

In patients with type 2 diabetes, both pioglitazone and rosiglitazone reduce HbA1c by about 1%, which is a similar change produced by other oral drugs such as metformin, glibenclamide, and glimepiride. [full review]

## How do thiazolidinediones compare in reducing the complications of diabetes?

There are insufficient data to determine whether pioglitazone and rosiglitazone differ in their ability to prevent the complications of diabetes, and whether they are more or less effective than other oral diabetes drugs. [full review]

## How do thiazolidinediones compare in prediabetes or the metabolic syndrome?

Currently, thiazolidinediones are not licensed to treat patients with prediabetes or metabolic syndrome.

There is insufficient evidence to determine whether one thiazolidinedione is superior to the other in their effect on weight in persons with prediabetes or metabolic syndrome. There are also insufficient data to determine whether one drug is superior to the other in slowing the progression of diabetes, or preventing diabetes altogether. [full review]

With respect to reducing cardiovascular disease risk factors, overall the evidence on how thiazolidinediones compare is insufficient. A single trial found that pioglitazone improved lipid levels compared to rosiglitazone, although other trials that compared each drug with placebo found mixed effects on lipid levels. There are no comparison data on the effects of thiazolidinediones on blood pressure, and the data on their effects on weight and abdominal obesity are limited. [full review]

## How do thiazolidinediones compare in safety?

When directly compared, pioglitazone and rosiglitazone shared similar adverse events, and when compared to placebo, both drugs were associated with similar drop-out rates from trials due to adverse events.

The incidence of edema was greater for both drugs compared to placebo, occurring in 4% of patients taking pioglitazone (95% CI 2 - 7%) and 8% of patients taking rosiglitazone (95% CI 3 - 13%).[full review]

## How do thiazolidinediones compare to sulfonylureas?

Sulfonylureas, such as chlorpropamide and glipizide, treat diabetes by stimulating insulin secretion.

Hypoglycemia (low blood sugar) is a potentially dangerous side effect. One study reported that there were fewer hypoglycemic events with pioglitazone than with a sulfonylurea. Four studies found that the incidence of hypoglycemia with rosiglitazone was variable compared to a sulfonylurea.

Overall, there is no evidence to determine whether thiazolidinediones are superior to sulfonylureas in terms of improving quality of life and enabling people to do normal daily activities. [full review]

## Does age or ethnicity influence the safety or effectiveness of thiazolidinediones?

It is not clear whether one drug is safer or more effective than the other in older adults. Indirect evidence suggests that pioglitazone and rosiglitazone are equally effective among racial/ethnic minorities, although the vast majority of studies examined Caucasian populations.

Evidence is lacking on how thiazolidinediones compare in persons with illnesses such as heart disease in addition to diabetes. [full review]

## Drugs included in this review

Generic Name | Trade Names
Pioglitazone | Actos
Rosiglitazone | Avandia

## Further information

[image]This PubMed Clinical Q&A was reviewed by Susan L. Norris, MD MPH MSc, and Susan Carson, MPH.

For the full report and evidence tables, please see: Norris SL, Carson S, Thakurta S, et al. Drug Class Review: Thiazolidinediones: Final Report Update 1 [Internet]. Portland (OR): Oregon Health & Science University; 2008 Aug. Available at: http://www.ncbi.nlm.nih.gov/books/NBK10739/.