# Comparing Fibromyalgia Drugs

Fibromyalgia is characterized by widespread pain as well as other symptoms such as sleep disorders, fatigue, and depression. The cause is unknown but may involve changes to the peripheral and central nervous systems.

Many different types of drugs have been used in an attempt to relieve symptoms of fibromyalgia–these include antidepressants, antiepileptics, and skeletal muscle relaxants. Of the drugs in this summary, only three have been approved by the FDA for the treatment of fibromyalgia: duloxetine (Cymbalta), milnacipran (Savella), and pregabalin (Lyrica).

The "Drug Class Review on Drugs for Fibromyalgia" compares the safety and effectiveness of 32 drugs. A summary of the findings is below.

## How do drugs for fibromyalgia compare in improving symptoms?

Overall, the strength of evidence was low. Of the limited direct comparisons available:

- IR paroxetine is better than amitriptyline in reducing pain and sleep disturbance in the short-term (6 weeks).
- No significant differences between amitriptyline compared to cyclobenzaprine at 4 weeks or compared to nortriptyline at 8 weeks.

From indirect comparisons (8-15 weeks):

- For the short-term, duloxetine is better than milnacipran for reducing pain, sleep disturbance, depressed mood, and health-related quality of life. At 28 weeks, however, there were no longer any significant differences between duloxetine and milnacipran.
- Both duloxetine and milnacipran are better than pregabalin for improving depressed mood, whereas pregabalin is better than milnacipran for improving sleep disturbance.
- Amitriptyline is similar to duloxetine, milnacipran, and pregabalin on outcomes of pain and fatigue.

Data are lacking for other drugs. [full review]

## How do drugs for fibromyalgia compare in safety?

In general, all drugs are well tolerated. Low-strength evidence suggests that overall adverse events are greater with amitriptyline than with IR paroxetine, and with nortriptyline than with amitriptyline. However, there were no significant differences in withdrawals due to adverse events between those or any other drugs. [full review]

## Does age, anxiety, or depression influence the safety or effectiveness of fibromyalgia drugs?

Low-strength evidence suggests that response to amitriptyline or cyclobenzaprine does not differ based on age. One small study found that duloxetine was not effective in reducing pain in older nonwhite males, but the study was underpowered to detect any difference.

In adults with anxiety, CR paroxetine and pregabalin improve fibromyalgia pain regardless of baseline anxiety. In adults with depressed mood, duloxetine, fluoxetine, CR paroxetine, and pregabalin all improve pain compared with placebo. Milnacipran was not effective in reducing fibromyalgia pain in nondepressed patients, but this finding should be interpreted with caution due to the small number of patients in this trial. [full review]

## Drugs included in this review

Generic name | Trade name
Tricyclic antidepressants
Amitriptyline | Elavil
Desipramine | Norpramin
Imipramine | Tofranil Tofranil-PM Impril
Nortriptyline | Aventyl Pamelor
Serotonin norepinephrine reuptake inhibitors
Desvenlafaxine | Pristiq
Venlafaxine | Effexor Effexor XR
Selective serotonin reuptake inhibitors
Citalopram | Celexa
Escitalopram | Lexapro Cipralex
Fluoxetine | Prozac Prozac weekly
Fluvoxamine | Luvox Luvox CR
Paroxetine | Paxil Paxil CR Pexeva
Sertraline | Zoloft
Selective serotonin and norepinephrine reuptake inhibitors
Duloxetine | Cymbalta
Milnacipran | Savella
Noradrenergic and specific serotonergic reuptake inhibitor
Mirtazapine | Remeron Remeron Soltab
Norepinephrine and dopamine reuptake inhibitor
Bupropion | Wellbutrin Wellbutrin Wellbutrin XL
Serotonin receptor antagonist
Nefazodone | N/A
Antiepileptic drugs
Carbamazepine | Tegretol Tegretol XR Carbatrol Equetro Mazepine
Divalproex | Depakote Depakote ER Epival
Ethotoin | Peganone
Gabapentin | Neurontin
Lacosamide | Vimpat
Lamotrigine | Lamictal Lamictal ODT Lamictal XR Lamictal CD
Levetiracetam | Keppra Keppra XR
Oxcarbazepine | Trileptal
Phenytoin | Dilantin
Pregabalin | Lyrica
Tiagabine | Gabitril
Topiramate | Topamax
Valproic acid | Depakene Depacon Stavzor
Zonisamide | Zonegran
Skeletal muscle relaxants
Cyclobenzaprine | Amrix Flexeril

## Further Information

[image]This PubMed Clinical Q&A was reviewed by Kimberly Peterson, MS.

For the full report and evidence tables, please see: Smith B, Peterson K, Fu R, McDonagh M, Thakurta S. Drug Class Review on Drugs for Fibromyalgia [Internet]. Portland (OR): Oregon Health & Science University; 2011 April. Available at http://www.ncbi.nlm.nih.gov/books/NBK55552/.