# Comparing Atypical Antipsychotics

Antipsychotics are mainly used to treat the symptoms of schizophrenia and bipolar disorder, but can also be used to treat major depression, dementia, and some specific childhood disorders.

Conventional antipsychotics can cause movement disorders, known as extrapyramidal side effects. These include tardive dyskinesia: repetitive movements that patients are unable to control, such as grimacing. Newer "atypical" antipsychotics such as olanzapine and risperidone are less likely to cause extrapyramidal side effects.

The "Drug Class Review on Atypical Antipsychotic Drugs" compares the safety and effectiveness of nine drugs. A summary of the findings is below.

## How do atypical antipsychotics compare in schizophrenia?

In the short term, there appear to be few differences between the atypical antipsychotics in adults with schizophrenia.

Clozapine is superior to olanzapine in preventing suicide attempts and worsening suicidal behavior in patients at high risk. Although more patients stop taking clozapine due to adverse events in the short term, in the longer term (up to 2 years), clozapine along with olanzapine have lower rates of discontinuation of drug for any reason compared to other antipsychotics.

Asenapine has higher rates of extrapyramidal side effects and more severe symptoms than olanzapine, and some studies also found risperidone and paliperidone had higher rates of extrapyramidal symptoms compared to olanzapine. However, the majority of studies found no differences among the drugs. Risperidone was found to result in more frequent or more severe sexual dysfunction symptoms than quetiapine, but was similar to extended-release paliperidone or ziprasidone.

Evidence is limited for how age, race, and gender influence the atypical antipsychotics. Among adolescents with schizophrenia, quetiapine was not superior to placebo based on response rate, but was superior based on improvements measured by the Positive and Negative Syndrome Scale. Differences by race were not found, but for gender, women had greater improvements than men with clozapine (on a global impression scale) and with olanzapine (on a quality of life scale). [details]

## How do atypical antipsychotics compare in bipolar disorder?

In adults with bipolar disorder who are experiencing a manic or mixed episode, no significant differences were found between risperidone and olanzapine or asenapine and olanzapine for quality of life, response, or remission outcomes.

Asenapine resulted in a higher risk of stopping the drug due to adverse events than olanzapine, but weight gain was greater with olanzapine. There were no differences in extrapyramidal symptoms. Weight gain was also greater with olanzapine compared to risperidone, but there were no differences in extrapyramidal symptoms or rates of discontinuations due to adverse events.

In adults with bipolar disorder who are experiencing a depressed episode, compared to placebo, only olanzapine and quetiapine (both immediate and extended-release) have evidence of significantly increasing the proportions of patients who achieve response and remission.

In children and adolescents, compared to placebo, the following drugs have all been shown to increase the proportions of children and adolescents who achieve treatment response and remission: aripiprazole, olanzapine, immediate-release quetiapine, and risperidone. Overall however, the evidence is limited. [details]

## How do atypical antipsychotics compare in depression?

The majority of studies evaluated the use of atypical antipsychotics in addition to standard antidepressants in patients with major depression who have failed to respond adequately to treatment. In such patients, comparisons to placebo found the rate of treatment response was improved by the addition of aripiprazole, quetiapine (immediate and extended-release), and risperidone. [details]

Observational evidence suggests that use of antidepressants (SSRIs) plus olanzapine is associated with significantly greater weight gain than SSRIs plus either quetiapine or risperidone. Evidence for other outcomes is limited. [details]

## How do atypical antipsychotics compare in dementia?

Patients with dementia may experience behavioral and psychological symptoms, e.g. depression, anxiety, and agitation. Antipsychotics are sometimes given to relieve these symptoms.

In patients with dementia, the best evidence found similar rates of response and withdrawal, and no differences in clinical outcome measures for olanzapine, risperidone, and quetiapine. [details]

## How do atypical antipsychotics compare in children with developmental and behavioral disorders?

Compared with placebo, risperidone, aripiprazole, and olanzapine improve behavioral symptoms in children with pervasive developmental disorders such as autism. [details]

Risperidone and quetiapine showed efficacy in children and adolescents with disruptive behavior disorders such as conduct disorder. [details]

## How do atypical antipsychotics compare in serious harms?

Olanzapine results in greater weight gain than other atypical antipsychotics (6 to 13 pounds more) and a 16% increased risk of new-onset diabetes, while risperidone resulted in an increased risk of new-onset tardive dyskinesia.

While clozapine has been shown to be associated with increased risk of seizures and agranulocytosis (severely low white cell count), differences among the drugs in other serious harms have not been clearly shown. Evidence on long-term harms for the newest drugs is lacking. [details]

## Drugs included in this review

Generic Name | Trade Names
Aripiprazole | Abilify Tablet Abilify Discmelt ODT Abilify Liquid Abilify Intramuscular Injection
Asenapine | Saphris Tablet
Clozapine | Clozaril Tablet Fazaclo ODT
Iloperidone | Fanapt Tablet
Olanzapine | ZyprexaTablet Zyprexa Zydis ODT Zyprexa Intramuscular Injection
Paliperidone | Invega ER Tablet Invega Sustenna ER Intramuscular
Quetiapine | Seroquel Tablet Seroquel XR Tablet
Risperidone | Risperdal Tablet, Liquid Risperdal M-TAB ODT Risperdal Consta Long-acting Intramuscular Injection
Ziprasidone | Geodon Capsule Geodon Intramuscular Injection Geodon Suspension

## Further information

[image]This PubMed Clinical Q&A was reviewed by Marian McDonagh, PharmD and Kimberly Peterson, MS.

For the full report and evidence tables, please see: McDonagh M, Peterson K, Carson S, et al. Drug Class Review: Atypical Antipsychotic Drugs: Final Update 3 Report [Internet]. Portland (OR): Oregon Health & Science University; 2010 Jul. Available at: http://www.ncbi.nlm.nih.gov/books/NBK505823/.