# Therapies for Treatment-Resistant Depression

A Review of the Research

## Is This Information Right for Me or Someone I Care For?

### Yes, if

- A doctor or health care professional has told you that you have major depressive disorder (MDD), or depression, [underlined: and]
- You have tried two different kinds of depression medicine, but you still have symptoms of depression.
- A doctor or health care professional has told you that you have treatment-resistant depression, or TRD.
- Your doctor or health care professional has suggested one or more of the following non-medicine treatments (therapies):
  - Electroconvulsive therapy (ECT)
  - Repetitive transcranial magnetic stimulation (rTMS)
  - Vagus nerve stimulation (VNS)
  - Talk therapy

### No, if

- A doctor has not diagnosed you with depression.
- You have not tried at least two different kinds of depression medicine.

### What does this summary cover?

This summary explains treatment-resistant depression. It tells you what the most recent research says about the treatments available when medicines do not help. It gives questions to ask about these treatment options.

### Where does the information come from?

The information comes from a report that reviewed 63 studies published between January 1980 and November 2010 for the Agency for Healthcare Research and Quality, a Federal Government research agency. You can read the full report at www.effectivehealthcare.ahrq.gov/trd.cfm.

## Understanding My Condition

### Why isn't the medicine working?

If your depression medicine didn't help you feel better, you are not alone. About half or more of all people treated with medicine for their depression will still have some symptoms or will have symptoms come back.

When your symptoms do not go away after trying two or more different medicines for 6 weeks or more, you may have what doctors call “treatment-resistant depression.”

#### Why do I have treatment-resistant depression?

There can be many reasons why a medicine works for some people and not others. Depression is a complex illness, and everyone is different. Your doctor or health care professional may want to talk about your symptoms again to see if there may be other reasons for why you feel depressed. You and your doctor can also explore other treatment options.

Many people do not get better the first or second time they treat their depression. Do not give up! You and your doctor can continue to look for the right treatment.

#### Is there anything that will work for me?

Doctors have many different ways to treat depression. Even if some medicines did not help you feel better, there are other treatment options. These options include combining medicines with non-medicine treatments, adding different medicines, or switching to one or more non-medicine therapies.

## Understanding My Options

### What are non-medicine treatments?

Although medicines are the most common way that doctors treat depression, there are other treatments (therapies) for depression that do not use medicines. Researchers have studied four of these treatments:

### Electroconvulsive Therapy

Electroconvulsive therapy, or ECT, is one of the oldest and most common non-medicine treatments for depression and other mental illnesses.

- ECT works by sending small amounts of electric current into one or both sides of the brain. This changes the way that the chemicals in your brain work.
- ECT is commonly used for treatment-resistant depression.
- An ECT session takes about 10 or 15 minutes and is done at a hospital or doctor's clinic. People are given anesthesia (pronounced an–es-THEE-zha), which are drugs used to put the person to sleep. You are not awake during an ECT treatment.
- A person may need two or three sessions per week for 2 to 4 weeks. The number of sessions depends on the persons condition and how soon the person starts to feel better.

#### What are the benefits of ECT?

ECT has been used for many years to help people with depression. Research about the benefits of ECT was not included in this review. Researchers think that ECT is most effective in helping people who are suicidal. Older people seem to benefit from ECT as well as younger people, if not more.

#### What are the side effects of ECT?

- Some people who have ECT have had seizures after the therapy.
- Some older research found that people who have had ECT may not think as well or as quickly after the therapy.
- There may be some side effects caused by the anesthesia such as low blood pressure, heart problems, or allergic reactions.
- People with unstable heart disease, bleeding problems, or extra pressure in their skulls should not have ECT.

#### What else should I think about?

- ECT has changed and has become safer than when it was first used. Many people with different kinds of mental illnesses have been treated with ECT.
- An ECT session costs around $2,500 per session, including anesthesia. There may be extra costs if a hospital stay is needed.
- ECT costs are covered by most health insurance plans, Medicaid, and Medicare. The amount you pay depends on your plan.

### Repetitive Transcranial Magnetic Stimulation

Repetitive transcranial magnetic stimulation, or rTMS, uses magnets to stimulate the nerve cells of the brain. A special device placed near the top of your head sends magnetic energy to the front part of your brain, called the “prefrontal cortex.” This part of your brain controls mood and depression.

The magnets send a pulse to your brain that excites the nerve cells. Researchers do not fully understand the exact way that rTMS works, but they think that the magnetic energy may help improve the way that the cells in your cortex send messages to each other.

rTMS is used for depression, other mental illnesses, epilepsy, and Parkinson's disease. The U.S. Food and Drug Administration has not approved it for treatment-resistant depression, but it has been used for people who didn't feel better after trying one medicine for 6 weeks or more.

- rTMS therapy sessions can be done in a doctor's office. rTMS does not require anesthesia (drugs used to put you to sleep). You are awake during the session.
- Sessions usually last 40 minutes.
- A person will have rTMS therapy every day (weekdays only) for 2 to 6 weeks. The number of weeks depends on the person's condition and how quickly the person starts to feel better.

#### What are the benefits of rTMS?

- Research found that people who had rTMS were three times as likely to experience some relief from their depression.
- Research found that people who had rTMS were six times as likely to have their depression go away completely. Researchers do not feel as confident about this result, because it came from only a few studies.
- rTMS may improve people's overall health and ability to function every day, but there is not enough research to know this for certain.
- There was not enough research to say if rTMS could keep depression symptoms from coming back.

#### What are the side effects of rTMS?

- There is not enough research to say how likely people might experience side effects because of rTMS therapy.
- rTMS may cause scalp pain in some people, but there is not enough research to know this for certain. Other side effects may include mild headaches, fainting, and temporary changes in hearing.

#### What else should I think about?

- rTMS is newer than other therapies. This means that there may not be as many places in your area that have the equipment for this treatment.
- rTMS is not approved for people who have treatment-resistant depression. This means that rTMS therapy is not covered by Medicaid and Medicare, and may not be covered by your health insurance plan. You may have to pay for the total cost of the treatment. The average total cost of rTMS treatment for most people is between $2,000 and $7,500.
- People with a high risk of seizures or who have implants or magnet-sensitive metal in their heads should not use rTMS.

### Vagus Nerve Stimulation

Vagus nerve stimulation, or VNS, uses a round battery-powered device that is implanted in your body during surgery. The device is placed in your chest with a wire that attaches to a nerve in your neck called the “vagus” nerve.

The wire sends an electrical impulse to your vagus nerve for 30 seconds every 5 minutes. It is usually kept inside the body for 10 weeks or more and then is removed. It was first made for people with epilepsy but is also used for people with treatment-resistant depression.

- VNS is usually only used for people who have not found relief from their depression after trying four or more depression medicines.
- VNS is used only for people who are 18 years of age or older.
- The surgery takes between 30 to 60 minutes. An overnight hospital stay may not be needed.

#### What are the benefits of VNS?

- There are not as many good studies about VNS to say how well it works.
- Limited research found that VNS did not improve the symptoms of depression.

#### What are the side effects of VNS?

- Some people had changes to their voice, a cough, neck pain, tingling or numbness in the skin, and shortness of breath.
- Since VNS requires an operation, people using this treatment are at risk for problems caused by surgery and anesthesia (drugs used to put you to sleep).

#### What else should I think about?

- The VNS device may be able to stay in your body for a long time.
- It may take 6 to 12 months before a person can see the benefits of VNS.
- VNS therapy is not covered by Medicaid and Medicare, and may not be covered by your health insurance plan. This means that you may have to pay for the entire cost. The average cost of treatment for most people, not including the cost of the operation, is between $10,000 and $20,000.

### “Talk” Therapy

Doctors may call this “cognitive behavioral therapy” or “interpersonal therapy” Trained therapists talk with people about how they think and feel about their depression. What the person and the therapist talk about is carefully planned by the therapist. The person and therapist might talk about specific symptoms or life events, ways to cope, or ways to address problems. Each session is part of a larger program of therapy to help the person feel better.

- Most talk therapy is done in 30-minute or 1-hour sessions once a week for 3 or 4 months, depending on the person.
- Some talk therapy is done in groups of people with a therapist rather than alone with the therapist.

#### What are the benefits of talk therapy?

There are not enough studies about how well talk therapy works for patients with treatment-resistant depression. Talk therapy has been studied for people with depression, eating disorders, anxiety, and personality disorders.

#### What are the side effects of talk therapy?

Research has not found any side effects from talk therapy.

#### What else should I think about?

- Talk therapy is covered by Medicare and most health insurance plans, although the number of therapy sessions you can have may be limited. The amount you pay depends on your plan. Most therapists charge around $150 per session.
- Finding the right therapist for you may make a difference in the success of this treatment. You may want to think about how the gender, age, race, or personality of the therapist makes you feel. Therapists are used to having people decide whether they want to work with them after the first visit. They will not be offended if you find someone else who makes you feel more comfortable.

### How do all these therapies compare with one another?

There is little research that compares each of these therapies against all the others. Although researchers can't say for sure, a very few studies found that:

- ECT seems to work better than a standard antidepressant to make depression symptoms better or go away completely.
- There are no clear differences between how well ECT or rTMS makes depression symptoms better or go away.
- There are no clear differences between how well ECT combined with rTMS makes depression symptoms better or go away when compared with having ECT by itself.
- Researchers cannot say whether there are more side effects from any one of the therapies over the others.
- Researchers cannot say whether there are more benefits from talk therapy than from medicines.

## Making a Decision

### What should I think about when deciding?

You and your doctor can decide together which option is best for you by considering:

- Other health conditions that may increase your risk of side effects.
- The specific nature of your depression and possible other causes for having treatment-resistant depression.
- Your values, likes, and dislikes about each of the options.
- Your goals for treatment and recovery from depression.
- Your insurance plan and the costs to you for each option.

If your depression is making it hard to talk about these issues, bring a trusted friend or family member along to the doctor's visit.

#### Talk with your doctor or health care professional

Here are some questions you may want to ask your doctor or health care professional at your next visit.

- Why do I have treatment-resistant depression?
- Would I do these treatments instead of taking medicine, or do I keep taking medicine for my depression?
- Do you have any worries about these treatments for me, given my health?
- If one choice doesn't work, what do you think is the next thing that I should try?
- When should I let you know that the treatment is working or not working?
- What is my risk for having side effects?

#### Write other questions here

___________________________________________________________________

___________________________________________________________________

___________________________________________________________________

___________________________________________________________________

___________________________________________________________________

___________________________________________________________________

#### Write the answers here

___________________________________________________________________

___________________________________________________________________

___________________________________________________________________

___________________________________________________________________

___________________________________________________________________

___________________________________________________________________

## Source

The information in this summary comes from the report Nonpharmacological Interventions for Treatment-Resistant Depression, September 2011.

The report was produced by the RTI International-University of North Carolina Evidence-based Practice Center through funding by the Agency for Healthcare Research and Quality (AHRQ).

For a copy of the report or for more information about AHRQ and the Effective Health Care Program, go to www.effectivehealthcare.ahrq.gov/trd.cfm. Additional information came from the MedlinePlus^®^ Web site, a service of the National Library of Medicine and the National Institutes of Health. This site is available at www.nlm.nih.gov/medlineplus.

This summary was prepared by the John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine, Houston, TX. Patients with depression reviewed this summary.