# Treatments for Fecal Incontinence

A Review of the Research for Adults

## Is This Information Right for Me?

### This information is right for you if

- Your health care professional^*^ said you or your loved one has fecal incontinence (FI). People with FI have trouble holding their stool until they can get to the bathroom. Stool sometimes leaks by accident. FI is also sometimes called “accidental bowel leakage.”
- You want to know what treatments are available for FI and what researchers have found about how well the treatments work.
- You or your loved one are age 18 or older. The information in this summary is from research on adults.

### What will this summary tell me?

This summary will answer these questions:

- What is FI?
- What are treatment options for FI?
- What have researchers found about how well FI treatments work?
- What are possible side effects or complications of the treatments?
- What should I discuss with my health care professional?

Note: This summary only discusses research on treatments for FI. It does not cover products that people with FI use, such as pads, disposable underwear, and skin care products.

### What is the source of this information?

Researchers funded by the Agency for Healthcare Research and Quality, a Federal Government research agency, reviewed studies on treatments for fecal incontinence published between 1980 and June 2015. The report included 63 studies comparing one treatment to another and 53 studies on only surgery for FI. The report was reviewed by health care professionals, researchers, experts, and the public. You can read the report at www.effectivehealthcare.ahrq.gov/fecal-incontinence.

## Understanding Your Condition

### What is fecal incontinence?

Fecal incontinence (FI) is a condition in which you have trouble holding your stool until you can get to the bathroom. Stool sometimes leaks by accident. The stool may be solid or liquid. FI is also sometimes called “accidental bowel leakage.”

Stool is the waste that passes out of your body during a bowel movement. Stool is made of undigested food and mucus. The mucus is a thick liquid that coats your digestive tract.

Any food that cannot be digested moves into your large intestine as waste. The last part of the large intestine is called the rectum. Waste stays in the rectum until it leaves your body through the anus during a bowel movement.

Muscles and nerves in the rectum and anus keep stool in the rectum until you are ready for a bowel movement. A ring of muscles called the anal sphincter (pronounced SFINK-ter) acts like a rubber band around the anus to keep it closed tightly. The pelvic floor muscles help support the bladder, rectum, and other organs. They also help control bowel movements.

### What causes FI?

FI can be caused by many things, including:

- Damage to the sphincter muscles or to the nerves that control the rectum and sphincter muscles
  » This can happen from childbirth, surgery involving the rectum or anus, or straining often to pass stool.
  » A spinal cord or brain injury can also damage the nerves that control the rectum and sphincter muscles.
- Loss of stretch or stiffening of the rectum
  » This can happen from surgery involving the rectum or anus, radiation treatment for cancer, or inflammatory bowel diseases (disorders that cause irritation to the lining of the lower digestive system).
- Swollen blood vessels in and around the lower rectum and anus (called hemorrhoids)
- A condition in which the rectum drops down through the anus (called rectal prolapse)
- Diarrhea
  » Loose stools are more difficult to hold in than solid stools.

### How common is FI?

- About 1 out of every 12 people in the United States has FI. That is equal to almost 18 million people.
- FI is more common in older adults and in women.

### What problems can FI cause?

Many people feel embarrassed and upset about their FI. They may avoid social situations because they are afraid of leaking stool. FI can severely limit a person's ability to enjoy work or activities. Untreated FI can lead to skin rashes, infections, and other problems.

## Understanding Your Options

### How is FI treated?

Many treatments have been used to help people with FI:

- Dietary fiber supplements
- Antidiarrhea medicines
- Bowel training
- Pelvic floor exercises (sometimes done with biofeedback)
- Anal sphincter bulking shots
- Surgery

#### Dietary Fiber Supplements

Dietary fiber supplements, such as psyllium, can help make your stool less loose. These supplements come as pills or powders.

#### Antidiarrhea Medicines

If your FI is caused by diarrhea, a medicine can help stop the diarrhea. Examples of antidiarrhea medicines include diphenoxylate (Lomotil^®^) or loperamide (Imodium^®^).

#### Bowel Training

Bowel training means trying to have a bowel movement at certain times of the day. You may try when you wake up each morning or after a meal. It may take several weeks or months to develop a regular pattern.

#### Pelvic Floor Muscle Training and Biofeedback

For pelvic floor muscle training (PFMT), you squeeze and release the muscles you use to stop a bowel movement. PFMT is sometimes done with biofeedback. Biofeedback helps you become more aware of how your muscles work. It uses sensors placed in the anus and rectum to make you feel like you need to have a bowel movement. The sensors then track when you squeeze your pelvic floor and anal sphincter muscles. This helps your health care professional see if you are squeezing your muscles the right way.

#### Anal Sphincter Bulking Shots

Anal sphincter bulking shots may help build up the tissue around the anus. The shots are given into the walls of the anus. They help to narrow the opening of the anus to help decrease stool leakage.

#### Surgery

Surgery may help FI that is caused by damaged nerves or muscles. Surgery is usually suggested only if other treatments do not work. There are several types of surgery for FI.

##### Sacral Nerve Stimulation

A small device is placed under the skin of your lower back. The device uses electrical pulses to stimulate the nerves that control the muscles in your rectum and anus. The area on your lower back will be numbed so you do not feel pain when the device is placed under the skin. The procedure is usually done in an outpatient center. The device runs on a battery that lasts about 5 years. When the battery runs out, you will need another procedure to replace the device.

##### Anal Sphincter Repair

If you have a tear in your anal sphincter, your doctor may recommend this type of surgery. A tear can be caused by childbirth or injury. The surgeon reconnects the ends of the muscles to fix the tear. This surgery is also called sphincteroplasty.

##### Anal Sphincter Replacement

The surgeon places a small cuff around the anus. The cuff connects to a small pump placed under the skin. When the cuff fills with air, it acts like the sphincter muscles to close the anus. To have a bowel movement, you squeeze the pump to let the air out of the cuff so the anus can open.

### What have researchers found about treatments for FI?

Treatment | What Researchers Found
The dietary fiber supplement psyllium | - Psyllium appears to reduce the number of times FI happens in some people after taking it for 1 month, but more research is needed to know this for sure.
Antidiarrhea medicines | - There is not enough research to know if or how well antidiarrhea medicines work to treat FI. This does not mean that they do not work, but more research is needed to know.
Bowel training | - There is not enough research to know if or how well bowel training works to treat FI. This does not mean that it does not work, but more research is needed to know.
Pelvic floor muscle training (PFMT) with biofeedback * | - For some people, PFMT with biofeedback appears to work about the same as anal sphincter bulking shots in the short term (for up to 6 months), but more research is needed to know this for sure.; - More research is needed to know how well PFMT with biofeedback works for longer than 6 months.
Anal sphincter bulking shots | - For some people, anal sphincter bulking shots appear to improve quality of life and reduce the number of times FI happens in the short term (for up to 6 months), but more research is needed to know this for sure.; - More research is needed to know how well the shots work for longer than 6 months.
Surgery for FI (sacral nerve stimulation, anal sphincter repair, and anal sphincter replacement) | - There is not enough research to know if or how well surgery works to treat FI. This does not mean that it does not work, but more research is needed to know.

* There is not enough research to know how well PFMT works by itself (without biofeedback).

### What are the possible side effects or complications of FI treatments?

All treatments for FI have possible side effects and complications (see the chart on the next page). Just because side effects and complications are possible does not mean you will have them.

Researchers found that:

- People who had surgery for FI had side effects and complications more often than people who used nonsurgery treatments.
- Side effects of nonsurgery treatments were usually mild.
- Complications of surgery were more severe.
- Complications happened most often with anal sphincter replacement surgery.

Treatment | Possible Side Effects or Complications
Nonsurgery treatments
The dietary fiber supplement psyllium | - Bloating; - Gas; - Stomach cramps
Antidiarrhea medicines diphenoxylate (Lomotil^®^) and loperamide (Imodium^®^) | - Nausea; - Pain or cramps in the belly; - Constipation
Bowel training | - No known side effects
Pelvic floor muscle training with biofeedback | - No known side effects
Anal sphincter bulking shots | - Bulking material from the shot leaking out; - Bleeding where the shot was given; - Infection; - Inflammation (redness, soreness, and swelling) of the rectum; - Pain or bleeding in the rectum; - Mucus leaking from the rectum; - Pain during a bowel movement; - Anal itching; - Diarrhea; - Constipation; - Fever
Surgery
Sacral nerve stimulation | - Infection; - Pain; - Problems with the device^*^
Anal sphincter repair | - Infection; - Sepsis^†^; - Anus becomes too narrow; - Intestine becomes blocked; - An abnormal tunnel, track, or hole that forms under the skin near the anus (called a fistula)
Anal sphincter replacement | - Infection; - Sepsis^†^; - Leaking or other problems with the surgery wound around the anus; - Pain

* You may need one or more additional surgeries to fix the problem or to replace or remove the device.

† Sepsis is a serious illness that happens when your immune system over-responds to an infection. It causes inflammation in your body. This could lead to blood clots and leaky blood vessels, very low blood pressure, and damage to your internal organs. You may need surgery to help get rid of the infection.

Note: Complications from anal sphincter repair and anal sphincter replacement often require another surgery. In severe cases, some complications may cause you to need a colostomy (pronounced cah-LOSS-tuh-mee). For a colostomy, the surgeon brings the end of your rectum through a small opening in the wall of your belly. As waste is made, it travels through your large intestine and rectum. Then waste travels through the opening in your belly and collects in a pouch outside of your body.

## Making a Decision

### What should I think about when deciding about treatment?

#### You may want to talk with your health care professional about

- Issues that concern you, such as needing to run to find a bathroom, needing to go to the bathroom often, being prepared for social situations, and controlling your FI
- The trade-offs between possible benefits and side effects or complications for each treatment
- The cost of the treatments and how much of the cost your insurance covers

#### Ask your health care professional

- Which treatment do you think may be best for me?
- Might changes in my diet help?
- If I have surgery, how long would my recovery be?
- How long will I need to continue treatment?
- How long will it take to know if the treatment is working? If the treatment does not help, when should I see you to try something different?
- How long will the treatment work? Might it stop working?
- What are the possible benefits and risks of the treatment?
- How will I know if I am having a side effect or complication, and when should I call you?
- How common are side effects or complications for each treatment? How severe might they be?

## Source

The information in this summary comes from the report Treatments for Fecal Incontinence, March 2016. The report was produced by the Minnesota Evidence-based Practice Center through funding by the Agency for Healthcare Research and Quality (AHRQ).

For a copy of the report or for more information about AHRQ, go to www.effectivehealthcare.ahrq.gov/fecal-incontinence.

Additional information came from the MedlinePlus^®^ Web site, a service of the National Library of Medicine and the National Institutes of Health. This site is available at www.medlineplus.gov.

This summary was prepared by the John M. Eisenberg Center for Clinical Decisions and Communications Science at Baylor College of Medicine, Houston, TX. People with fecal incontinence reviewed this summary.

* Your health care professional may include your primary care physician, gastroenterologist (a doctor who specializes in the digestive system), proctologist (a doctor who specializes in diseases of the colon, rectum, and anus), gynecologist (a doctor who specializes in the female reproductive system), urogynecologist (a doctor who specializes in disorders of the pelvic floor), surgeon, nurse practitioner, or physician assistant.