# References and Included Studies

1 Robert G, Milne R. Positron emission tomography: establishing priorities for health technology assessment. Health Technol Assess. 1999;3(16).
2 Al-Nahhas AM, Win Z, Singh A, et al. The role of 18F-FDG-PET in oncology: Clinical and resource implications. Nucl Med Rev. 2006;9:1-5.
3 Laupacis AD, Alter M, Mamdami M, et al. Health technology assessment of positron emission tomography (PET) a systematic review. ICES Investigative Report. Toronto. Institute for Clinical and Evaluative Sciences. 2001.
4 Jaeschke R, Guyatt G, Sackett D. Users’ guides to the medical literature. III. How to use an article about a diagnostic test. A. Are the results of the study valid? Evidence-Based Medicine Working Group. JAMA. 1994;271(5):389-91. [pmid: 8283589].
5 EMEA (European Agency for the Evaluation of Medicinal Products). Points to consider on the evaluation of diagnostic agents. London (UK). EMEA. 2001.
6 Ioannidis JA, Lau J. 18F-FDG-PET for the diagnosis and grading of soft-tissue sarcome: a meta-analysis. J Nucl Med. 2003;44:717-24. [pmid: 12732672].
7 Havrilesky LJ, Kuasingam SL, Matchar DB, et al. FDG-PET for management of cervical and ovarian cancer. Gynecol Oncol. 2005;97:183-91. [pmid: 15790456].
8 Orlando LA, Kulasingam SL, Matchar DB. Meta-analysis: the detection of pancreatic malignancy with positron emission tomography. Aliment Pharmacol Ther. 2004;20(10):1063-70. [pmid: 15569108].
9 Delgado-Bolton RC, Carreras JL, Perez-Castejon MAJ. A systematic review of the efficacy of 18F-FDG-PET in unknown primary tumors. Curr Med Imaging Rev. 2006;2(2):215-25.
10 Medicare National Coverage Determinations Manual. Chapter 1, Part 4 (Sections 200 310.1) Coverage Determinations. Revised. 2007. [web page]. Available at: http://www.cms.hhs.gov/manuals/downloads/ncd103c1_Part4.pdf. April 9, 2008.
11 Evers S, Goosens M, de Vet H, et al. Criteria list for assessment of methodological quality of economic evaluations: Consensus on Health Economic Criteria. Int J Technol Assess Health Care. 2005;21(2):240-5. [pmid: 15921065].
12 Berger M, Gould MK, Barnett PG. The cost of positron emission tomography in six United States Veterans Affairs Hospitals and two academic medical centres. AJR. 2003;181:359-65. [pmid: 12876011].
13 Virnig B, Durham S. Post coverage analysis: use of positron emission tomography (PET) scans. Minneapolis (MN). Research Data Assistance Center, University of Minnesota. 2004.
14 Natchar DB, Kulasingam SL, Havrilesky L, et al. Positron emission testing for six cancers (brain, cervicall, small cel lung, ovarian, pacreatic and testicular). Rockville (MD). Agency for Health Care Research and Quality. 2004.
15 Hillner BE, Siegel BA, Liu D, et al. Impact of positron emission tomography/computed tomography and positron emission tomography (PET) alone on expected management of patients with cancer: initial results from the national oncologic PET registry. J Clin Oncol. 2008;26(13):2155-61. [pmid: 18362365].
16 Fryback DG, Thornbury JR. The efficacy of diagnostic imaging. Med Decis Making. 1991;11:88-94. [pmid: 1907710].
17 Scottish Intercollegiate Guidelines Network. Methodology checklist 5: studies of diagnostic accuracy. [web page]. Available at http://www.sign.ac.uk/guidelines/fulltext/50/checklist5.html. Mar 20, 2008.
18 Whiting J, Rutjes AW, Dinnes J, et al. Development and validation of methods for assessing the quality of diagnostic accuracy studies. Health Tech Assess. 2004;8(25).
19 DerSimonian R. Meta-analysis in the design and monitoring of clinical trials. Stat Med. 1996;15:1237-52. [pmid: 8817798].
20 Halkin A, Reichman J, Schwaber M, et al. Likelihood ratios: getting diagnostic testing into perspective. QJM. 1998;91:247-58. [pmid: 9666947].
21 Moses LE, Shapiro D, Littenberg B. Combining independent studies of a diagnostic test into a summary ROC curve: data-analytic approaches and some additional considerations. Stat Med. 1993;12:1293-316. [pmid: 8210827].
22 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. 2003;327(557-60).
23 Drieskens O, Oyen R, Van Poppel H, et al. FDG-PET for preoperative staging of bladder cancer. Eur J Nucl Med Mol Imaging. 2005;32(12):1412-7. [pmid: 16133380].
24 Jadvar H, Quan V, Henderson RW, et al. [F-18]-Fluorodeoxyglucose PET and PET-CT in diagnostic imaging evaluation of locally recurrent and metastatic bladder transitional cell carcinoma. Int J Clin Oncol. 2008;13(1):42-7. [pmid: 18307018].
25 Liu IJ, Segall GM, Nino-Murcia M, et al. Fluorodeoxyglucose positron emission tomography studies in the diagnosis and staging of transitional cell carcinoma. Adv Exp Med Biol. 2003;539(Pt A):129-42. [pmid: 15088902].
26 Chen W, Silverman DH, Delaloye S, et al. 18F-FDOPA PET imaging of brain tumors: comparison study with 18F-FDG-PET and evaluation of diagnostic accuracy. J Nucl Med. 2006;47(6):904-11. [pmid: 16741298].
27 Cher LM, Murone C, Lawrentschuk N, et al. Correlation of hypoxic cell fraction and angiogenesis with glucose metabolic rate in gliomas using 18F-fluoromisonidazole, 18F-FDG-PET, and immunohistochemical studies. J Nucl Med. 2006;47(3):410-8. [pmid: 16513609].
28 Liu RS, Chang CP, Chu LS, et al. PET imaging of brain astrocytoma with 1-11C-acetate. Eur J Nucl Med Mol Imaging. 2006;33(4):420-7. [pmid: 16404596].
29 Potzi C, Becherer A, Marosi C, et al. [11C] methionine and [18F] fluorodeoxyglucose PET in the follow-up of glioblastoma multiforme. J Neuro-Oncol. 2007;84(3):305-14.
30 Stockhammer F, Thomale UW, Plotkin M, et al. Association between fluorine-18-labeled fluorodeoxyglucose uptake and 1p and 19q loss of heterozygosity in World Health Organization Grade II gliomas. J Neurosurg. 2007;106(4):633-7. [pmid: 17432715].
31 Amit A, Beck D, Lowenstein L, et al. The role of hybrid PET/CT in the evaluation of patients with cervical cancer. Gynecol Oncol. 2006;100(1):65-9. [pmid: 16269172].
32 Bjurberg M, Kjellen E, Ohlsson T, et al. FDG-PET in cervical cancer: staging, re-staging and follow-up. Acta Obstet Gynecol Sc. 2007;86(11):1385-91.
33 Chang TC, Law KS, Hong JH, et al. Positron emission tomography for unexplained elevation of serum squamous cell carcinoma antigen levels 168 during follow-up for patients with cervical malignancies: a phase II study. Cancer. 2004;101(1):164-71. [pmid: 15222002].
34 Chang WC, Hung YC, Lin CC, et al. Usefulness of FDG-PET to detect recurrent cervical cancer based on asymptomatically elevated tumor marker serum levels: a preliminary report. Cancer Invest. 2004;22(2):180-4. [pmid: 15199599].
35 Chang YC, Yen TC, Ng KK, et al. Does diabetes mellitus influence the efficacy of FDG-PET in the diagnosis of cervical cancer?. Eur J Nucl Med Mol Imaging. 2005;32(6):647-52. [pmid: 15703931].
36 Choi HJ, Roh JW, Seo SS, et al. Comparison of the accuracy of magnetic resonance imaging and positron emission tomography/computed tomography in the presurgical detection of lymph node metastases in patients with uterine cervical carcinoma: a prospective study. Cancer. 2006;106(4):914-22. [pmid: 16411226].
37 Chou HH, Chang TC, Yen TC, et al. Low value of [18F]-fluoro-2-deoxy-D-glucose positron emission tomography in primary staging of early-stage cervical cancer before radical hysterectomy. J Clin Oncol. 2006;24(1):123-8. [pmid: 16382121].
38 Chung HH, Jo H, Kang WJ, et al. Clinical impact of integrated PET/CT on the management of suspected cervical cancer recurrence. Gynecol Oncol. 2007;104(3):529-34. [pmid: 17049971].
39 Chung HH, Kim SK, Kim TH, et al. Clinical impact of FDG-PET imaging in post-therapy surveillance of uterine cervical cancer: from diagnosis to prognosis. Gynecol Oncol. 2006;103(1):165-70. [pmid: 16574205].
40 Grisaru D, Almog B, Levine C, et al. The diagnostic accuracy of 18F-Fluorodeoxyglucose PET/CT in patients with gynecological malignancies. Gynecol Oncol. 2004;94(3):680-4. [pmid: 15350358].
41 Havrilesky LJ, Wong TZ, Secord AA, et al. The role of PET scanning in the detection of recurrent cervical cancer. Gynecol Oncol. 2003;90(1):186-90. [pmid: 12821362].
42 Hope AJ, Saha P, Grigsby PW. FDG-PET in carcinoma of the uterine cervix with endometrial extension. Cancer. 2006;106(1):196-200. [pmid: 16302228].
43 Lai CH, Huang KG, See LC, et al. Restaging of recurrent cervical carcinoma with dual-phase [18F]fluoro-2-deoxy-D-glucose positron emission tomography. Cancer. 2004;100(3):544-52. [pmid: 14745871].
44 Lin CT, Yen TC, Chang TC, et al. Role of [18F]fluoro-2-deoxy-D-glucose positron emission tomography in re-recurrent cervical cancer. Int J Gynecological Cancer. 2006;16(6):1994-2003.
45 Lin WC, Hung YC, Yeh LS, et al. Usefulness of (18)F-fluorodeoxyglucose positron emission tomography to detect para-aortic lymph nodal metastasis in advanced cervical cancer with negative computed tomography findings. Gynecol Oncol. 2003;89(1):73-6. [pmid: 12694656].
46 Loft A, Berthelsen AK, Roed H, et al. The diagnostic value of PET/CT scanning in patients with cervical cancer: a prospective study. Gynecol Oncol. 2007;106(1):29-34. [pmid: 17482666].
47 Ma SY, See LC, Lai CH, et al. Delayed (18)F-FDG-PET for detection of paraaortic lymph node metastases in cervical cancer patients. J Nucl Med. 2003;44(11):1775-83. [pmid: 14602859].
48 Park W, Park YJ, Huh SJ, et al. The usefulness of MRI and PET imaging for the detection of parametrial involvement and lymph node metastasis in patients with cervical cancer. Jpn J Clin Oncol. 2005;35(5):260-4. [pmid: 15886267].
49 Roh JW, Seo SS, Lee S, et al. Role of positron emission tomography in pretreatment lymph node staging of uterine cervical cancer: a prospective surgicopathologic correlation study. Eur J Cancer. 2005;41(14):2086-92. [pmid: 16125928].
50 Ryu SY, Kim MH, Choi SC, et al. Detection of early recurrence with 18F-FDG-PET in patients with cervical cancer. J Nucl Med. 2003;44(3):347-52. [pmid: 12620999].
51 Sakurai H, Suzuki Y, Nonaka T, et al. FDG-PET in the detection of recurrence of uterine cervical carcinoma following radiation therapy--tumor volume and FDG uptake value. Gynecol Oncol. 2006;100(3):601-7. [pmid: 16257440].
52 Sironi S, Picchio M, Landoni C, et al. Post-therapy surveillance of patients with uterine cancers: value of integrated FDG-PET/CT in the detection of recurrence. Eur J Nucl Med Mol Imaging. 2007;34(4):472-9. [pmid: 17106701].
53 Sironi S, Buda A, Picchio M, et al. Lymph node metastasis in patients with clinical early-stage cervical cancer: detection with integrated FDG-PET/CT. Radiology. 2006;238(1):272-9. [pmid: 16304090].
54 Tran BN, Grigsby PW, Dehdashti F, et al. Occult supraclavicular lymph node metastasis identified by FDG-PET in patients with carcinoma of the uterine cervix. Gynecol Oncol. 2003;90(3):572-6. [pmid: 13678726].
55 Unger JB, Ivy JJ, Ramaswamy MR, et al. Whole-body [18F]fluoro-2-deoxyglucose positron emission tomography scan staging prior to planned radical hysterectomy and pelvic lymphadenectomy. Int J Gynecological Cancer. 2005;15(6):1060-4.
56 Unger JB, Ivy JJ, Connor P, et al. Detection of recurrent cervical cancer by whole-body FDG-PET scan in asymptomatic and symptomatic women. Gynecol Oncol. 2004;94(1):212-6. [pmid: 15262145].
57 Van Der Veldt AAM, Hooft L, Van Diest PJ, et al. Microvessel density and p53 in detecting cervical cancer by FDG-PET in cases of suspected recurrence. Eur J Nucl Med Mol Imaging. 2006;33(12):1408-16. [pmid: 16841142].
58 Wong TZ, Jones EL, Coleman RE. Positron emission tomography with 2-deoxy-2-[(18)F]fluoro-D-glucose for evaluating local and distant disease in patients with cervical cancer. Mol Imaging Biol. 2004;6(1):55-62. [pmid: 15018829].
59 Wright JD, Dehdashti F, Herzog TJ, et al. Preoperative lymph node staging of early-stage cervical carcinoma by [18F]-fluoro-2-deoxy-D-glucose-positron emission tomography. Cancer. 2005;104(11):2484-91. [pmid: 16270319].
60 Yen TC, Lai CH, Ma SY, et al. Comparative benefits and limitations of [18]F-FDG-PET and CT-MRI in documented or suspected recurrent cervical cancer. Eur J Nucl Med Mol Imaging. 2006;33(12):1399-407. [pmid: 16847653].
61 Yen TC, See LC, Chang TC, et al. Defining the priority of using 18F-FDG-PET for recurrent cervical cancer. J Nucl Med. 2004;45(10):1632-9. [pmid: 15471826].
62 Yen TC, Ng KK, Ma SY, et al. Value of dual-phase 2-fluoro-2-deoxy-d-glucose positron emission tomography in cervical cancer. [erratum appears in J Clin Oncol. 2004 Jan 1;22(1):209]. J Clin Oncol. 2003;21(19):3651-8. [pmid: 14512397].
63 Yildirim Y, Sehirali S, Avci ME, et al. Integrated PET/CT for the evaluation of para-aortic nodal metastasis in locally advanced cervical cancer patients with negative conventional CT findings. Gynecol Oncol. 2008;108(1):154-9. [pmid: 17945337].
64 Aide N, Cappele O, Bottet P, et al. Efficiency of [(18)F]FDG-PET in characterising renal cancer and detecting distant metastases: a comparison with CT. Eur J Nucl Med Mol Imaging. 2003;30(9):1236-45. [pmid: 12845486].
65 Ak I, Can C. F-18 FDG-PET in detecting renal cell carcinoma. Acta Radiol. 2005;46(8):895-9. [pmid: 16392617].
66 Chang CH, Shiau YC, Shen YY, et al. Differentiating solitary pulmonary metastases in patients with renal cell carcinomas by 18F-fluoro-2-deoxyglucose positron emission tomography: a preliminary report. Urol Int. 2003;71(3):306-9. [pmid: 14512653].
67 Dilhuydy MS, Durieux A, Pariente A, et al. PET scans for decision-making in metastatic renal cell carcinoma: a single-institution evaluation. Oncology. 2006;70(5):339-44. [pmid: 17164590].
68 Jadvar H, Kherbache HM, Pinski JK, et al. Diagnostic role of [F-18]-FDG positron emission tomography in restaging renal cell carcinoma. Clin Nephrol. 2003;60(6):395-400. [pmid: 14690256].
69 Kang DE, White RL Jr, Zuger JH, et al. Clinical use of fluorodeoxyglucose F18 positron emission tomography for detection of renal cell carcinoma. J Urol. 2004;171(5):1806-9. [pmid: 15076281].
70 Kumar R, Chauhan A, Lakhani P, et al. 2-Deoxy-2-[F-18]fluoro-D-glucose-positron emission tomography in characterization of solid renal masses. Mol Imaging Biol. 2005;7(6):431-9. [pmid: 16307216].
71 Majhail NS, Urbain JL, Albani JM, et al. F-18 fluorodeoxyglucose positron emission tomography in the evaluation of distant metastases from renal cell carcinoma. J Clin Oncol. 2003;21(21):3995-4000. [pmid: 14581422].
72 Bristow RE, Giuntoli RL 2nd, Pannu HK, et al. Combined PET/CT for detecting recurrent ovarian cancer limited to retroperitoneal lymph nodes. Gynecol Oncol. 2005;99(2):294-300. [pmid: 16051330].
73 Bristow RE, del Carmen MG, Pannu HK, et al. Clinically occult recurrent ovarian cancer: patient selection for secondary cytoreductive surgery using combined PET/CT. Gynecol Oncol. 2003;90(3):519-28. [pmid: 13678719].
74 Castellucci P, Perrone AM, Picchio M, et al. Diagnostic accuracy of 18F-FDG-PET/CT in characterizing ovarian lesions and staging ovarian cancer: correlation with transvaginal ultrasonography, computed tomography, and histology. Nucl Med Commun. 2007;28(8):589-95. [pmid: 17625380].
75 Chung HH, Kang WJ, Kim JW, et al. Role of [18F]FDG-PET/CT in the assessment of suspected recurrent ovarian cancer: correlation with clinical or histological findings. Eur J Nucl Med Mol Imaging. 2007;34(4):480-6. [pmid: 17089122].
76 Drieskens O, Stroobants S, Gysen M, et al. Positron emission tomography with FDG in the detection of peritoneal and retroperitoneal metastases of ovarian cancer. Gynecol Obstet Invest. 2003;55(3):130-4. [pmid: 12865590].
77 Garcia-Velloso MJ, Jurado M, Ceamanos C, et al. Diagnostic accuracy of FDG-PET in the follow-up of platinum-sensitive epithelial ovarian carcinoma. Eur J Nucl Med Mol Imaging. 2007;34(9):1396-405. [pmid: 17318549].
78 Hauth EA, Antoch G, Stattaus J, et al. Evaluation of integrated whole-body PET/CT in the detection of recurrent ovarian cancer. Eur J Radiol. 2005;56(2):263-8. [pmid: 16233894].
79 Kawahara K, Yoshida Y, Kurokawa T, et al. Evaluation of positron emission tomography with tracer 18-fluorodeoxyglucose in addition to magnetic resonance imaging in the diagnosis of ovarian cancer in selected women after ultrasonography. J Comput Assist Tomogr. 2004;28(4):505-16. [pmid: 15232382].
80 Kim CK, Park BK, Choi JY, et al. Detection of recurrent ovarian cancer at MRI: comparison with integrated PET/CT. J Comput Assist Tomogr. 2007;31(6):868-75. [pmid: 18043348].
81 Murakami M, Miyamoto T, Iida T, et al. Whole-body positron emission tomography and tumor marker CA125 for detection of recurrence in epithelial ovarian cancer. Int J Gynecological Cancer. 2006;16(Suppl 1):99-107.
82 Nanni C, Rubello D, Farsad M, et al. (18)F-FDG-PET/CT in the evaluation of recurrent ovarian cancer: a prospective study on forty-one patients. Eur J Surg Oncol. 2005;31(7):792-7. [pmid: 15893908].
83 Pannu HK, Cohade C, Bristow RE, et al. PET-CT detection of abdominal recurrence of ovarian cancer: radiologic-surgical correlation. Abdom Imaginging. 2004;29(3):398-403.
84 Picchio M, Sironi S, Messa C, et al. Advanced ovarian carcinoma: usefulness of (18)F-FDG-PET in combination with CT for lesion detection after primary treatment. Q J Nucl Med. 2003;47(2):77-84. [pmid: 12865867].
85 Risum S, Hogdall C, Loft A, et al. The diagnostic value of PET/CT for primary ovarian cancer--a prospective study. Gynecol Oncol. 2007;105(1):145-9. [pmid: 17229460].
86 Sebastian S, Lee SI, Horowitz NS, et al. PET-CT vs. CT alone in ovarian cancer recurrence. Abdom Imaging. 2008;33(1):112-8. [pmid: 17404789].
87 Sironi S, Messa C, Mangili G, et al. Integrated FDG-PET/CT in patients with persistent ovarian cancer: correlation with histologic findings. Radiology. 2004;233(2):433-40. [pmid: 15516617].
88 Takekuma M, Maeda M, Ozawa T, et al. Positron emission tomography with 18F-fluoro-2-deoxyglucose for the detection of recurrent ovarian cancer. Int J Clin Oncol. 2005;10(3):177-81. [pmid: 15990965].
89 Thrall MM, DeLoia JA, Gallion H, et al. Clinical use of combined positron emission tomography and computed tomography (FDG-PET/CT) in recurrent ovarian cancer. Gynecol Oncol. 2007;105(1):17-22. [pmid: 17208284].
90 Yoshida Y, Kurokawa T, Kawahara K, et al. Incremental benefits of FDG positron emission tomography over CT alone for the preoperative staging of ovarian cancer. AJR Am J Roentgenol. 2004;182(1):227-33. [pmid: 14684544].
91 Bang S, Chung HW, Park SW, et al. The clinical usefulness of 18-fluorodeoxyglucose positron emission tomography in the differential diagnosis, staging, and response evaluation after concurrent chemoradiotherapy for pancreatic cancer. J Clin Gastroenterol. 2006;40(10):923-9. [pmid: 17063113].
92 Borbath I, Van Beers BE, Lonneux M, et al. Preoperative assessment of pancreatic tumors using magnetic resonance imaging, endoscopic ultrasonography, positron emission tomography and laparoscopy. Pancreatology. 2005;5(6):553-61. [pmid: 16113592].
93 Casneuf V, Delrue L, Kelles A, et al. Is combined [18]F-fluorodeoxyglucose-positron emission tomography/computed tomography superior to positron emission tomography or computed tomography alone for diagnosis, staging and restaging of pancreatic lesions?. Acta Gastro-Ent Belg. 2007;70(4):331-8.
94 Giorgi MC, Cunha RM, Soares J Jr, et al. Dual-head gamma camera coincidence imaging in pancreatic cancer. Rev Esp Med Nucl. 2004;23(2):90-4. [pmid: 15000938].
95 Heinrich S, Goerres GW, Schafer M, et al. Positron emission tomography/computed tomography influences on the management of resectable pancreatic cancer and its cost-effectiveness. Ann Surg. 2005;242(2):235-43. [pmid: 16041214].
96 Lemke AJ, Niehues SM, Hosten N, et al. Retrospective digital image fusion of multidetector CT and 18F-FDG-PET: clinical value in pancreatic lesions--a prospective study with 104 patients. J Nucl Med. 2004;45(8):1279-86. [pmid: 15299049].
97 Lytras D, Connor S, Bosonnet L, et al. Positron emission tomography does not add to computed tomography for the diagnosis and staging of pancreatic cancer. Dig Surg. 2005;22(1–2):55-62. [pmid: 15838173].
98 Maemura K, Takao S, Shinchi H, et al. Role of positron emission tomography in decisions on treatment strategies for pancreatic cancer. J Hepatobil Pancreat Surg. 2006;13(5):435-41.
99 Mansour JC, Schwartz L, Pandit-Taskar N, et al. The utility of F-18 fluorodeoxyglucose whole body PET imaging for determining malignancy in cystic lesions of the pancreas. J Gastrointest Surg. 2006;10(10):1354-60. [pmid: 17175454].
100 Nishiyama Y, Yamamoto Y, Monden T, et al. Evaluation of delayed additional FDG-PET imaging in patients with pancreatic tumour. Nucl Med Commun. 2005;26(10):895-901. [pmid: 16160649].
101 Nishiyama Y, Yamamoto Y, Yokoe K, et al. Contribution of whole body FDG-PET to the detection of distant metastasis in pancreatic cancer. Ann Nucl Med. 2005;19(6):491-7. [pmid: 16248386].
102 Rasmussen I, Sorensen J, Langstrom B, et al. Is positron emission tomography using 18F-fluorodeoxyglucose and 11C-acetate valuable in diagnosing indeterminate pancreatic masses?. Scand J Surg. 2004;93(3):191-7. [pmid: 15544073].
103 Ruf J, Lopez Hanninen E, Bohmig M, et al. Impact of FDG-PET/MRI image fusion on the detection of pancreatic cancer. Pancreatology. 2006;6(6):512-9. [pmid: 17106215].
104 Ruf J, Lopez Hanninen E, Oettle H, et al. Detection of recurrent pancreatic cancer: comparison of FDG-PET with CT/MRI. Pancreatology. 2005;5(2–3):266-72. [pmid: 15855825].
105 perti C, Bissoli S, Pasquali C, et al. 18-fluorodeoxyglucose positron emission tomography enhances computed tomography diagnosis of malignant intraductal papillary mucinous neoplasms of the pancreas. Ann Surg. 2007;246(6):932-9. [pmid: 18043094].
106 van Kouwen MC, Jansen JB, van Goor H, et al. FDG-PET is able to detect pancreatic carcinoma in chronic pancreatitis. Eur J Nucl Med Mol Imaging. 2005;32(4):399-404. [pmid: 15549297].
107 Wakabayashi H, Nishiyama Y, Otani T, et al. Role of 18F-fluorodeoxyglucose positron emission tomography imaging in surgery for pancreatic cancer. World J Gastroenterol. 2008;14(1):64-9. [pmid: 18176963].
108 Chang CH, Wu HC, Tsai JJ, et al. Detecting metastatic pelvic lymph nodes by 18F-2-deoxyglucose positron emission tomography in patients with prostate-specific antigen relapse after treatment for localized prostate cancer. Urol Int. 2003;70(4):311-5. [pmid: 12740497].
109 Jadvar H, Pinski JK, Conti PS. FDG-PET in suspected recurrent and metastatic prostate cancer. Oncol Reports. 2003;10(5):1485-8.
110 Oyama N, Miller TR, Dehdashti F, et al. 11C-acetate PET imaging of prostate cancer: detection of recurrent disease at PSA relapse. J Nucl Med. 2003;44(4):549-55. [pmid: 12679398].
111 Schoder H, Herrmann K, Gonen M, et al. 2-[18F]fluoro-2-deoxyglucose positron emission tomography for the detection of disease in patients with prostate-specific antigen relapse after radical prostatectomy. Clin Cancer Res. 2005;11(13):4761-9. [pmid: 16000572].
112 Blum R, MacManus MP, Rischin D, et al. Impact of positron emission tomography on the management of patients with small-cell lung cancer: preliminary experience. Am J Clin Oncol. 2004;27(2):164-71. [pmid: 15057156].
113 Bradley JD, Dehdashti F, Mintun MA, et al. Positron emission tomography in limited-stage small-cell lung cancer: a prospective study. J Clin Oncol. 2004;22(16):3248-54. [pmid: 15310768].
114 Brink I, Schumacher T, Mix M, et al. Impact of [18F]FDG-PET on the primary staging of small-cell lung cancer. Eur J Nucl Med Mol Imaging. 2004;31(12):1614-20. [pmid: 15258700].
115 Fischer BM, Mortensen J, Langer SW, et al. A prospective study of PET/CT in initial staging of small-cell lung cancer: comparison with CT, bone scintigraphy and bone marrow analysis. Ann Oncol. 2007;18(2):338-45. [pmid: 17060487].
116 Fischer BM, Mortensen J, Langer SW, et al. PET/CT imaging in response evaluation of patients with small cell lung cancer. Lung Cancer. 2006;54(1):41-9. [pmid: 16919841].
117 Kamel EM, Zwahlen D, Wyss MT, et al. Whole-body (18)F-FDG-PET improves the management of patients with small cell lung cancer. J Nucl Med. 2003;44(12):1911-7. [pmid: 14660716].
118 Kut V, Spies W, Spies S, et al. Staging and monitoring of small cell lung cancer using [18F]fluoro-2-deoxy-D-glucose-positron emission tomography (FDG-PET). Am J Clin Oncol. 2007;30(1):45-50. [pmid: 17278894].
119 Niho S, Fujii H, Murakami K, et al. Detection of unsuspected distant metastases and/or regional nodes by FDG-PET [corrected] scan in apparent limited-disease small-cell lung cancer. [erratum appears in Lung Cancer. 2007 Dec;58(3):432]. Lung Cancer. 2007;57(3):328-33. [pmid: 17537538].
120 Pandit N, Gonen M, Krug L, et al. Prognostic value of [18F]FDG-PET imaging in small cell lung cancer. Eur J Nucl Med Mol Imaging. 2003;30(1):78-84. [pmid: 12483413].
121 Vinjamuri M, Craig M, Campbell-Fontaine A, et al. Can positron emission tomography be used as a staging tool for small-cell lung cancer?. Clin Lung Cancer. 2008;9(1):30-4. [pmid: 18282355].
122 Becherer A, De Santis M, Karanikas G, et al. FDG-PET is superior to CT in the prediction of viable tumour in post-chemotherapy seminoma residuals. Eur J Radiol. 2005;54(2):284-8. [pmid: 15837411].
123 Hinz S, Schrader M, Kempkensteffen C, et al. The role of positron emission tomography in the evaluation of residual masses after chemotherapy for advanced stage seminoma. J Urol. 2008;179(3):936-40. [pmid: 18207171].
124 Karapetis CS, Strickland AH, Yip D, et al. Use of fluorodeoxyglucose positron emission tomography scans in patients with advanced germ cell tumour following chemotherapy: single-centre experience with long-term follow up. Intern Med J. 2003;33(9–10):427-35. [pmid: 14511195].
125 Lassen U, Daugaard G, Eigtved A, et al. Whole-body FDG-PET in patients with stage I non-seminomatous germ cell tumours. Eur J Nucl Med Mol Imaging. 2003;30(3):396-402. [pmid: 12634968].
126 Mangili G, Picchio M, Sironi S, et al. Integrated PET/CT as a first-line re-staging modality in patients with suspected recurrence of ovarian cancer. Eur J Nucl Med Mol Imaging. 2007;34(5):658-66. [pmid: 17180659].
127 Simcock B, Neesham D, Quinn M, et al. The impact of PET/CT in the management of recurrent ovarian cancer. Gynecol Oncol. 2006;103(1):271-6. [pmid: 16626793].
128 Soussan M, Wartski M, Cherel P, et al. Impact of FDG-PET-CT imaging on the decision making in the biologic suspicion of ovarian carcinoma recurrence. Gynecol Oncol. 2008;108(1):160-5. [pmid: 17961640].
129 Padma MV, Said S, Jacobs M, et al. Prediction of pathology and survival by FDG-PET in gliomas. J Neuro-Oncol. 2003;64(3):227-37.
130 Kim S, Chung JK, Kang SB, et al. [18F]FDG-PET as a substitute for second-look laparotomy in patients with advanced ovarian carcinoma. Eur J Nucl Med Mol Imaging. 2004;31(2):196-201. [pmid: 15129701].
131 Kirkali Z, Chan T, Manoharan M, et al. Bladder cancer: epidemiology, staging and grading, and diagnosis. Urology. 2005;66(suppl 6A):4-34. [pmid: 16399414].
132 Babjuk M, Oosterlinck W, Sylvester R, et al. EAU guidelines on non-muscle-invasive urothelial carcinoma of the bladder. Eur Urol. 2008. Apr. 30. Epub ahead of print.
133 Ries LAG, Melbert D, Krapcho M, et al. SEER Cancer Statistics Review, 1975–2005. Bethesda (MD). National Cancer Institute. 2008.
134 Kitamura H, Tsukamoto T. Early bladder cancer: concept, diagnosis, and management. Int J Clin Oncol. 2006;11(1):28-37. [pmid: 16508726].
135 Sylvester RJ, van der Meijden A, Witjes JA, et al. High-grade Ta urothelial carcinoma and carcinoma in situ of the bladder. Urology. 2005;66(suppl 6a):90-107. [pmid: 16399418].
136 Troung MT. Current role of radiation therapy in the mangement of malignant brain tumors. Hematol Oncol Clin N Am. 2006;20(2):431-53.
137 Fisher JL, Schwartzbaum JA, Wrensch M, et al. Epidemology of brain tumors. Neurol Clin. 2007;25(4):867-90. [pmid: 17964019].
138 Chandana SR, Movva S, Arora M ST. Primary brain tumors in adults. Am Fam Physician. 2008;77(10):1423-30. [pmid: 18533376].
139 Safaeian M, Solomon D, Castle PE. Cervical cancer prevention - cervical screening: science in evolution. Obstet Gynecol Clin North Am. 2007;34(4):739-60. [pmid: 18061867].
140 Cannistra SA, Niloff JM. Cancer of the uterine cervix. NEJM. 1996;334(16):1030-8. [pmid: 8598842].
141 Whitcomb BP. Gynecologic malignancies. Surg Clin North Am. 2008;88(2):301-17. [pmid: 18381115].
142 Rose PG. Chemoradiotherapy for cervical cancer. Eur J Cancer. 2002;38(2):270-8. [pmid: 11803143].
143 Petignat P, Roy M. Diagnosis and management of cervical cancer. BMJ. 2007;335(7623):765-8. [pmid: 17932207].
144 Jadvar H, Conti P. The reproductive tract. Semin Nucl Med. 2004;34(4):262-73. [pmid: 15493004].
145 Singh AK, Grigsby PW, Dehdashti F, et al. FDG-PET lymph node staging and survival of patients with FIGO stage IIIb cervical carcinoma. Int J Radiat Oncol Biol Phys. 2003;56(2):489-93. [pmid: 12738325].
146 Rini BI, Rathmell WK, et al. Renal cell carcinoma. Curr Opin Oncol. 2008;20(3):300-6. [pmid: 18391630].
147 Corgna E, Betti M, Gatta G, et al. Renal Cancer. Crit Rev Oncol. 2007;64(3):247-62.
148 Holshneider CH, Berek JS. Ovarian cancer: epidemiology, biology and prognostic factors. Semin Surg Oncol. 2000;19(1):3-10. [pmid: 10883018].
149 Modugno F. Ovarian Cancer and High-Risk Woman Symposium Presenters. Ovarian cancer and high-risk women: implications for prevention, screening, and early detection. Gynecol Oncol. 2003;91(1):15-31. [pmid: 14529658].
150 Scully RE. Classification of human ovarian tumors. Environ Health Perspect. 1987;73:15-24. [pmid: 3665859].
151 Abei S, Castiglione M. Epithelial ovarian carcinoma: ESMO clinical recommendations for diagnosis, treatment and follow-up. Ann Oncol. 2008;19(suppl2):ii14-6. [pmid: 18456751].
152 Freelove R, Walling AD. Pancreatic cancer: diagnosis and management. Am Fam Physician. 2006;73(3):485-92. [pmid: 16477897].
153 Goonetilleke KS, Siriwardena AK. Current status of gene expression profiling of pancreatic cancer. Int J Surg. 2008;6(1):81-3. [pmid: 18359465].
154 Li D, Xie K, Wolff R, et al. Pancreatic cancer. Lancet. 2004;363:1049-57. [pmid: 15051286].
155 Michl P, Pauls S, Gress TM. Evidence-based diagnosis and staging of pancreatic cancer. Best Pract Res Clin Gastroenterol. 2006;20(2):227-51. [pmid: 16549326].
156 Horwich A, Parker C, Kataja V, et al. Prostate cancer: ESMO clinical recommendations for diagnosis, treatment and follow-up. Ann Oncol. 2008;19(suppl2):ii45-6. [pmid: 18456765].
157 U.S. Cancer Statistics Working Group. United States cancer statistics: 2004 incidence and mortality. 2007. U.S. Department of Health and Human Services, Centers for Disease Control and Prevention and National Cancer Institute. Atlanta (GA).
158 National Cancer Institute. Bethesda M. Cancer advances in focus: prostate cancer. [web page]. Available at http://www.cancer.gov/cancertopics/cancer-advances-in-focus/prostate.pdf. June 16, 2008.
159 National Cancer Institute. Bethesda M. Prostate Cancer Screening (PDQ^®^). [web page]. Available at: http://www.nci.nih.gov/cancertopics/pdq/screening/prostate/healthprofessional/allpages#Section_20. June 16, 2008.
160 Damber JE AG. Prostate cancer. Lancet. 2008;371(9625):1710-21. [pmid: 18486743].
161 Gleason DF, Mellinger GT. Prediction of prognosis for prostatic adenocarcinoma by combined histological grading and clinical staging. J Urol. 1974;111(1):58-64. [pmid: 4813554].
162 Jewett HJ. The present status of radical prostatectomy for stages A and B prostatic cancer. Urol Clin North Am. 1975;2(1):105-24. [pmid: 1128746].
163 Prostate American Joint Committee on Cancer AJCC Cancer Staging Manual. 6th ed ed. New York (NY). Springer. 2002:309-16.
164 Dahm P, Yeung LL, Chang SS, et al. A critical review of clinical practice guidelines for the management of clinically localized prostate cancer. J Urol. 2008;180:451-60. [pmid: 18550100].
165 Wilt TJ, MacDonald R, Rutks I, et al. Systematic review: comparative effectiveness and harms of treatments for clinically localized prostate cancer. Ann Intern Med. 2008;148(6):435-48. [pmid: 18252677].
166 Lin AM, Small EJ. Prostate cancer update: 2007. Curr Opin Oncol. 2008;20(3):294-9. [pmid: 18391629].
167 Robinson JW, Saliken JC, Donnelly BJ, et al. Quality-of-life outcomes for men treated with cryosurgery for localized prostate carcinoma. Cancer. 1999;86(9):1793-801. [pmid: 10547553].
168 Alibhai SM, Klotz LH. A systematic review of randomized trials in localized prostate cancer. Can J Urol. 2004;11(1):2110-7. [pmid: 15003149].
169 Ferraldeschi R, Baka S, Jyoti B, et al. Modern management of small-cell lung cancer. Drugs. 2007;67(15):2135-52. [pmid: 17927281].
170 Sher T, Dy Gk, Adjei AA. Small cell lung cancer. Mayo Clin Proc. 2008;83(3):355-67. [pmid: 18316005].
171 Govindan R, Page N, Morgensztern D, et al. Changing epidemiology of small-cell lung cancer in the United States over the last 30 years: analysis of the surveillance, epidemiologic and end results database. J Clin Oncol. 2006;24(28):4539-44. [pmid: 17008692].
172 Chua YJ, Steer C, Yip D. Recent advances in management of small-cell lung cancer. Cancer Treat Rev. 2004;30(6):521-43. [pmid: 15325033].
173 Leo F, Pastorino U. Surgery in small-cell lung carcinoma: where is the rationale?. Sem Surg Oncol. 2003;21(3):176-81.
174 Shepherd FA, Crowly J, Van Houtte P, et al. International association for the study of lung cancer lung cancer staging project: proposals regarding the clinical staging of small cell lung cancer in the forthcoming (seventh) edition of the tumor, node, metastasis classification for lung cancer. J Thor Oncol. 2007;2(12):1067-77.
175 Feldman DR, Bosl George J, Sheinfeld J, et al. Medical treatment of advanced testicular cancer. JAMA. 2008;299(6):672-84. [pmid: 18270356].
176 National Cancer Institute. Bethesda M. Testicular cancer: questions and answers. [web page]. Available at http://www.cancer.gov/cancertopics/factsheet/Sites-Types/testicular.
177 Shaw J. Diagnosis and treatment of testicular cancer. Am Fam Physician. 2008;77(4):469-74. [pmid: 18326165].
178 Krege S, Beyer J, Souchon R, et al. European consensus conference on diagnosis and treatment of germ cell cancer: a report of the second meeting of the European Germ Cell Cancer Consensus Group (EGCCCG): part I. Eur Urol. 2008;53(3):478-96. [pmid: 18191324].
179 Machtens S, Serth J, Meyer A, et al. World J Urol. 2007;25(4):341-9. [pmid: 17624533].
180 Jafri SZ, Dinan D, Francis IR, et al. Pretreatment staging of invasive bladder cancer. Reston (VA). American College of Radiology. 2007.
181 Ascher SM, Brown JJ, Walsh JW. Diagnostic Imaging techniques in gynecologic oncology Principles and Practice of Gynecologic Oncology. 2 ed. Philidelphia. Lippincott-Raven Publishers. 1997.
182 Dose J, Kotzerke J, Schicha H, et al. Clinical value of FDG-PET in the diagnosis of gynecological tumors: recommendations of the 3rd interdisciplinary german Consensus conference PET in Oncology III. Geburtsh Frauenheilk. 2002;62(7):644-51.
183 Javitt MC, Fleischer AC, Andreotti RF, et al. Staging and follow-up of ovarian cancer. Reston (VA). American College of Radiology. 2007.
184 FDG positron emission tomography in pancreas. Chicago, IL. Blue Cross and Blue Shield Association. 2000.
185 Higashi T, Saga T, Nakamoto Y, et al. Diagnosis of pancreatic cancer using fluorine-18 fluorodeoxyglucose positron emission tomography (FDG-PET): usefulness and limitations in “clinical reality”. Ann Nuclear Med. 2003;17(4):261-79.
186 Pound CR, Partin AW, Eisenberger MA, et al. Natural history of progression after PSA elevation following radical prostatectomy. JAMA. 1999;281:1591-7. [pmid: 10235151].
187 Anscher MS. Salvage therapy for recurrent prostate cancer: the earlier the better. JAMA. 2004;291:1380-2. [pmid: 15026405].
188 Pignon JP, Arriagada R, Ihde DC, et al. Effect of thoracic radiotherapy on mortality in limited small cell lung cancer. A meta-analysis of 13 randomized trials among 2,140 patients. N Engl J Med. 1992;327:1618-24. [pmid: 1331787].
189 Papanicolaou N, Francis IR, Baumgarten DA, et al. taging of testicular malignancy. Reston (VA). American College of Radiology. 2007.
190 Mallet S, Deeks JJ, Halligan S, et al. Systematic reviews of diagnostic tests in cancer: review of methods and reporting. BMJ. 2006;333:413. [pmid: 16849365].