# Executive Summary

## Introduction

The University of Alberta Evidence-based Practice Center (UAEPC) reviewed and synthesized the published literature on the use of ^18^FDG-PET in the assessment and treatment of nine types of cancer with respect to the following clinical situations: diagnosis, staging, restaging, and monitoring response to treatment. The research questions were organized under four key questions:

- ^18^FDG-PET and ^18^FDG-PET/CT diagnostic test performance;
- Diagnostic thinking impact of ^18^FDG-PET and ^18^FDG-PET/CT;
- ^18^FDG-PET and ^18^FDG-PET/CT as part of a management strategy; and
- Cost-effectiveness of ^18^FDG-PET and ^18^FDG-PET/CT.

Positron emission tomography (PET) is a form of nuclear medicine imaging that detects and establishes metabolic abnormalities in tissue. Compared to structural imaging techniques (X-ray, computed tomography [CT], and magnetic resonance imaging [MRI]), ^18^FDG-PET is considered a potentially major advancement in clinical practice because it may provide information about the behavior of tumors in addition to the anatomic extent and thus can provide evidence to guide therapeutic choices. In the United States, the Centers for Medicaid and Medicare Services (CMS) has determined that there is sufficient evidence to show that a ^18^FDG-PET scan is reasonable and necessary for certain indications in the pretreatment and management phase of non-small cell lung cancer, esophageal cancer, colorectal cancer, lymphoma, melanoma, breast cancer, head and neck cancers and thyroid cancer. There is a need to evaluate the evidence emerging recently on the benefits of ^18^FDG-PET for other oncologic indications.

## Methods

The UAEP established a prospectively designed protocol for this technology report. To accomplish the tasks as directed, a core research team composed of clinical investigators and methodologists was assembled. Comprehensive searches were conducted in four relevant electronic databases for the time period from 2003 to March 2008. Two independent reviewers applied a set of inclusion and exclusion criteria to determine eligibility of potentially relevant studies. Disagreements about the inclusion or exclusion of studies were resolved by consensus among reviewers. Studies should be published in English, with more than 12 adult participants with primary cancer of the following type: bladder, brain, cervical, kidney, ovarian, pancreatic, prostate, small cell lung, and testicular, and providing quantitative data on at least one outcome of interest. Restrictions regarding study design were not imposed.

Trained research assistants extracted the data using a comprehensive and pretested data extraction form. One reviewer verified the accuracy and completeness of the data. The methodological quality of studies on the diagnostic performance and the diagnostic thinking impact of ^18^FDG-PET and ^18^FDG-PET/CT was assessed using the Scottish Intercollegiate Guidelines Network (SIGN) assessment tool for diagnostic studies. An individual components approach that considered important aspects of design, conduct, and reporting of effectiveness studies was used to assess the methodological quality of studies assessing the impact of ^18^FDG-PET and ^18^FDG-PET/CT as part of a management strategy to improve patient-centered outcomes. Finally, the methodological quality of economic evaluations of ^18^FDG-PET and ^18^FDG-PET/CT was assessed using the Consensus on Health Economic Criteria (CHEC). Studies were graded according to a system adopted by the Veterans Affairs Technology Assessment Program (VATAP) to classify the level of evidence regarding the clinical utility of studies on PET. Two reviewers assessed the methodological quality of studies independently. Disagreements were resolved by consensus.

A combination of qualitative and quantitative approaches was used to synthesize the data. Details of individual studies were summarized in evidence tables including information on article source, study design, study population, characteristics of ^18^FDG-PET and ^18^FDG-PET/CT and reference tests, and outcomes. Two-by-two tables were constructed for studies on the diagnostic test performance of ^18^FDG-PET and ^18^FDG-PET/CT. Sensitivity and specificity were calculated for each study. Individual study results were grouped when two or more studies assessed the same type of PET for similar purposes (e.g., primary diagnosis, staging, restaging, recurrences), had similar study design (i.e., prospective or retrospective), and had usable data for common outcomes of interest. Summary estimates of the likelihood ratio, both positive and negative were meta-analyzed using the DerSimonian and Laird random effects method to support inferences regarding the magnitude and direction of the diagnostic performance of ^8^FDG-PET and ^18^FDG-PET/CT.

## Results

One hundred and nine articles were included in this report. The results are presented by type of cancer.

Bladder cancer: Evidence from three studies is available on the diagnostic performance of ^18^FDG-PET and ^18^FDG-PET/CT for bladder cancer. Data from a meta-analysis of two prospective studies totalling 88 participants showed that ^18^FDG-PET does not seem to be helpful in identifying the stage of the disease. The diagnostic accuracy of ^18^FDG-PET and ^18^FDG-PET/CT has not been evaluated for other clinical situations. Only one study of moderate sample size and moderate quality evaluated the diagnostic thinking impact of ^18^FDG-PET on the treatment of bladder cancer and reported that 17 percent of the treatment decisions were changed after knowing the results of ^18^FDG-PET. Since the amount and quality of the evidence is limited, firm conclusions about the diagnostic thinking impact of ^18^FDG-PET in bladder cancer cannot be drawn.

Brain cancer. Six studies provided evidence on the use of ^18^FDG-PET for brain cancer. We did not find studies that reported on the use of ^18^FDG-PET/CT for brain cancer. The majority of the studies evaluated the diagnostic accuracy of ^18^FDG-PET. ^18^FDG-PET does not seem to be highly discriminative in identifying the stage of the disease, and in distinguishing between necrosis and recurrences. The sensitivity and specificity values of the studies were modest and had wide confidence intervals, precluding firm conclusions about the diagnostic utility of ^18^FDG-PET for brain cancer. The effects of ^18^FDG-PET as part of a management strategy on patient-centered outcomes continue to be scarcely evaluated. There is limited evidence from low quality studies that the best indication of ^18^FDG-PET seems to be differentiating between high and low grade gliomas. There is, however, no consensus regarding the utility of ^18^FDG-PET in predicting histological grading and survival of brain tumors.

Cervical cancer. ^18^FDG-PET and ^18^FDG-PET/CT have been evaluated for a variety of clinical indications in the assessment of patients with cervical cancer. These include 1) initial staging, 2) detection of recurrence, and 3) restaging, including planning for salvage therapy. There is evidence around the diagnostic accuracy for each of these indications, and also limited evidence for the diagnostic thinking impact. Only two studies provided evidence for the effects of ^18^FDG-PET on patient-centered outcomes and these addressed problems of detection of recurrence and restaging. There is no data on the cost effectiveness of either ^18^FDG-PET or ^18^FDG-PET/CT. The strongest evidence for the diagnostic accuracy of ^18^FDG-PET or ^18^FDG-PET/CT has been produced for staging of locally advanced cervical cancer and the detection and restaging of recurrent disease.

Kidney cancer. There is some evidence to suggest that the accuracy of ^18^FDG-PET may be sufficient to support its use in the initial staging of renal cancer. When ^18^FDG-PET was compared against any reference standard in prospective studies, statistically significant results were obtained for both the positive and negative likelihood ratios. Because of the high sensitivities and specificities reported in prospective studies of diagnostic accuracy, the application of ^18^FDG-PET to at least initial staging of renal cancer seems to be worthy of additional study by well-designed prospective trials. There is insufficient evidence to support its widespread adoption at this time.

Ovarian cancer. ^18^FDG-PET and ^18^FDG-PET/CT have been evaluated for a variety of clinical indications in the assessment of patients with ovarian cancer. These include 1) primary diagnosis, 2) initial staging, 3) detection of recurrence and 3) restaging. There is evidence around the diagnostic accuracy for each of these indications, and also limited evidence for the diagnostic thinking impact. Only one study provided evidence for the effects of ^18^FDG-PET as part of a management strategy on patient-centered outcomes, and there is no data on the cost effectiveness of either ^18^FDG-PET or ^18^FDG-PET/CT for ovarian cancer. Most of the studies have evaluated the use of ^18^FDG-PET/CT. ^18^FDG-PET has not been studied in women with suspected ovarian cancer for primary diagnostic purposes. The evidence on the efficacy of ^18^FDG-PET and ^18^FDG-PET/CT for the initial staging of ovarian cancer is very limited and no firm conclusions can be made regarding their utility for this indication. The clinical indication for which ^18^FDG-PET has been evaluated the most is for the detection of recurrences following treatment. Meta-analyses of the diagnostic accuracy of both ^18^FDG-PET and ^18^FDG-PET/CT showed a consistent, statistically significant effect in both the positive and negative LRs across a range of reference standards and study designs, providing evidence to support the usefulness of ^18^FDG-PET and ^18^FDG-PET/CT in detecting ovarian cancer recurrences.

Pancreatic cancer. Seventeen studies evaluated the diagnostic accuracy of ^18^FDG-PET or ^18^FDG-PET/CT. The majority of studies are on ^18^FDG-PET but some of them have evaluated ^18^FDG-PET/CT. The findings were consistently significant, suggesting that both ^18^FDG-PET and ^18^FDG-PET/CT are useful in diagnosing and establishing initial stage of the disease. Further, there is no clear evidence for the choice of ^18^FDG-PET v. ^18^FDG-PET/CT, since the observed heterogeneity indicates considerable uncertainty in these estimates. We found that when ^18^FDG-PET was evaluated for primary diagnostic purposes, the positive LR was slightly better for ruling in the disease, but the negative LR remained almost the same. There is some evidence on the diagnostic thinking impact of ^18^FDG-PET and ^18^FDG-PET/CT that indicates that the management plan is altered in an important number of patients (up to 69 percent), more often resulting in a conservative course of management thus avoiding unnecessary surgery. Finally, one study conducted a cost-minimization analysis on the use of ^18^FDG-PET/CT for pancreatic cancer. The analysis, however, is insufficient to demonstrate changes in costs relative to changes in clinical effects due to the implementation of ^18^FDG-PET/CT in the diagnostic workup of pancreatic cancer.

Prostate cancer. The studies identified for analysis in this technology assessment addressed only the detection of recurrence in patients with an increased PSA following primary therapy for prostate cancer. No study addressed the diagnosis or staging of disease. Due to heterogeneity across studies in terms of study design, type of PET and indications for its use, no pooled estimate of the accuracy of ^18^FDG-PET could be obtained. The impact of ^18^FDG-PET on diagnostic thinking or patient-centered outcomes was not assessed in any studies. Furthermore, there is no data available describing the use of ^18^FDG-PET/CT technology.

Small cell lung cancer. There is no evidence to support the role of ^18^FDG-PET or ^18^FDG-PET/CT in the diagnosis of SCLC and no cost-effectiveness data is available for this tumour for any indication. However, there is preliminary evidence from three cohort studies of moderate quality supporting the technique’s use in staging and restaging.

Testicular cancer. The recent evidence for ^18^FDG-PET in testicular cancer is very limited and inconclusive. Four studies of moderate quality evaluated the diagnostic accuracy of ^18^FDG-PET for testicular cancer. ^18^FDG-PET/CT has not been evaluated for this condition. The clinical indications that were evaluated included initial staging, restaging and recurrences; however, a pooled analyzes of the data was precluded due to the limited number of studies. One small retrospective study of moderate methodological quality evaluated the physician decision-making impact when ^18^FDG-PET imaging is used in the assessment of the recurrence of testicular cancer. The management plan was changed in only a small proportion of the patients, suggesting that ^18^FDG-PET imaging had minimal effect on subsequent treatment decisions. Finally, none of the studies evaluated the effects of ^18^FDG-PET or ^18^FDG-PET/CT as part of a management strategy on patient-centered outcomes. There were no economic evaluations on the use of ^18^FDG-PET or ^18^FDG-PET/CT and therefore, no firm conclusions on the clinical and economic impact of ^18^FDG-PET or ^18^FDG-PET/CT can be made.

## Future Research

Further evaluations of the utility of this technology should be done with developments concentrating on enhancing patient throughput and establishing new and more focused clinical applications in various subpopulations of patients. Because it may be quite challenging to enrol patients into a study for low-incidence cancers, multicenter studies will be required to adequately address these important issues.

Finally, some of the most important roles of ^18^FDG-PET and ^18^FDG-PET/CT have not been sufficiently explored (e.g., estimating prognosis, selecting and changing treatment modalities, estimating their role in the evaluation of tumor burden regardless of histology). Evaluations of the procedures or therapies forestalled or cancelled based on ^8^FDG-PET and ^18^FDG-PET/CT must be explored further to inform policy decisions, these information gaps need to be filled with new methodological approaches.

## Conclusions

For some type of cancers (e.g., cervical, ovarian, and pancreatic cancer), there is some evidence of the utility of ^18^FDG-PET or ^18^FDG-PET/CT for diagnosing, staging, or detecting recurrences, but they may still require more studies to augment the evidence base. Further studies are needed to reach firm conclusions about the clinical effectiveness of ^18^FDG-PET and ^18^FDG-PET/CT in terms of the impact on diagnosis and treatment options, patient-centered outcomes, and economic costs. It is still unclear how ^18^FDG-PET and ^18^FDG-PET/CT affects patient treatment and ultimately their outcome. For other types of cancer examined in the review (e.g., bladder, kidney, prostate, SCLC, and testicular) the answers are still inconclusive and require more careful study.