# Acknowledgments

The following members of the University of Alberta Evidence-based Practice Center have contributed to the preparation of this report:

- Liza Bialy, B.Sc.
- Kenneth Bond, B.Ed, M.A.
- Nina Buscemi, Ph.D.
- Donna M Dryden, Ph.D.
- Lisa Hartling, M.Sc.
- Krystal Harvey, B.Sc.
- Mohammad Karkhaneh, M.D., Ph.D (Cand)
- Andrea Milne, B.Sc.N.

Many thanks to Thane Chambers, M.L.I. S. from the John W. Scott Health Sciences Library at the University of Alberta for designing the literature search strategies of this technology report.