# Conclusions

## Strengths and Limitations

The strengths of this technology report pertain to its rigour in terms of searching the literature, the criterion-based selection of relevant evidence, the rigorous appraisal of validity, the quantitative summary of data, and the evidence-based inferences.

Our search strategy is likely to have identified the majority of the available literature on ^18^FDG-PET or ^18^FDG-PET/CT for the nine types of cancer addressed in this report.

We particularly targeted the indexed literature, however we acknowledge the possibility that the review may not be fully comprehensive, as we did not include evidence presented in abstracts of scientific meetings.

We provided detailed information on the review procedures (e.g., duplicate study selection, quality assessment by two assessors, and verification of data extraction to increase review reliability.)

We adopted a comprehensive strategy to appraise the methodological quality of the included studies. Our approach to quality focused mainly on an assessment of the internal validity of the studies as recommended by several researchers. 190

Our decisions to include or exclude studies into meta-analysis of the diagnostic accuracy of ^18^FDG-PET or ^18^FDG-PET/CT were transparent and documented. For each study, summary statistics of test performance (e.g., sensitivity and specificity) were used to report the results of individual studies.

One of the limitations of this review is the restriction of included studies to English-language publications. We did not include foreign language literature because of the difficulties in translation. Twenty-one studies were excluded for this reason, with the majority of them being published in Japanese and Chinese languages. The magnitude of bias that the exclusion of foreign literature may have produced in the results of the pooled estimates of the positive and negative LRs is unknown.

The review included only studies with sample sizes of 12 or more adult participants. There are advantages and disadvantages to including small studies in systematic reviews of diagnostic tests. By including small studies, the power and precision of the pooled estimates would increase (in fact, some may argue that this is precisely the strength behind any meta-analysis). Likewise, avoiding sample size considerations may be one of the main strengths of a systematic review. However, there are some disadvantages of including studies with very small numbers: they can introduce numeric instability in the accuracy estimates, and since small studies may be more prone to selection bias (due to non-consecutive patient sampling) and publication bias, their inclusion may incorporate biased data into the summary estimates. Limiting inclusion of studies based on sample size considerations seems to be a common practice when conducting systematic reviews of diagnostic tests.190 To note, only 32 studies were excluded from the review based on sample-size considerations. Further research is needed to identify the best approach to solve the problems associated with the inclusion of small studies in systematic reviews and meta-analyses of diagnostic tests.

Another potential limitation is that only studies published from 2003 and forward were included in the review. Most of the scientific literature published before 2003 was covered in the Duke report 14 for six of the cancers considered in our review (i.e., brain, cervical, ovarian, pancreatic, SCLC, and testicular); however, a number of studies published before 2003 for three types of cancers that were not considered in the Duke report (i.e., prostate, bladder and kidney) have been left out. However, the technology around FDG-PET has evolved dramatically over the last few years and it is expected that there is substantial variation between “old” and “new” studies in the manufacture and procedures for this technology.

Finally, a variety of diagnostic tests can be used in isolation or in combination with ^18^FDG-PET and ^18^FDG-PET/CT for the nine cancers that were considered in this review. The value of ^18^FDG-PET and ^18^FDG-PET/CT may differ by patient depending on the results of previous imaging, and the presence of various clinical signs and symptoms. The studies included in the review reported on individual values of ^18^FDG-PET and ^18^FDG-PET/CT and therefore, the review does not provide information about the aggregated diagnostic value from adding other tests to inform important therapeutic decisions. When interpreting the impact and value that ^18^FDG-PET and ^18^FDG-PET/CT may have on patient management decisions for a given patient, the clinical context must be taken into consideration.

## Conclusions and Future Areas of Research

For some type of cancers (e.g., cervical, ovarian, and pancreatic cancer), there is some evidence of the utility of ^18^FDG-PET or ^18^FDG-PET/CT for diagnosing, staging, or detecting recurrences, but additional studies are required to augment the evidence base. Particularly, further studies are needed to reach firm conclusions about the clinical effectiveness of ^18^FDG-PET and ^18^FDG-PET/CT in terms of the impact on diagnosis and treatment options, patient-centered outcomes, and economic costs. It is still unclear how ^18^FDG-PET and ^18^FDG-PET/CT affect patient treatment and ultimately their outcome. For other types of cancer examined in the review (e.g., bladder, kidney, prostate, SCLC, and testicular) the utility of these tests is inconclusive and requires more careful study.

The strongest evidence for the diagnostic accuracy of ^18^FDG-PET or ^18^FDG-PET/CT has been produced for staging of locally advanced cervical cancer and the detection and restaging of recurrent disease, the detection of ovarian cancer recurrences following treatment, and the diagnosing and initial staging of pancreatic cancer. These and other indications require further research to show the impact of^18^FDG-PET or ^18^FDG-PET/CT on patient management or added value in the diagnostic and therapeutic process.

Although PET technology development appears to have reached maturity with the fusion of ^18^FDG-PET and CT in an integrated system, imaging protocols will continue to be refined over the next few years. Further evaluations of the utility of this technology should be done with developments concentrating on enhancing patient throughput and establishing new and more focused clinical applications in various subpopulations of patients. Because it may be quite challenging to enrol patients into a study for low-incidence cancers, multicenter studies will be required to adequately address these important issues.

Finally, some of the most important roles of ^18^FDG-PET and ^18^FDG-PET/CT have not been sufficiently explored (e.g., estimating prognosis, selecting and changing treatment modalities, estimating their role in the evaluation of tumor burden regardless of histology). Evaluations of the procedures or therapies forestalled or cancelled based on ^8^FDG-PET and ^18^FDG-PET/CT must be explored further. If the total clinical contributions of ^18^FDG-PET and ^18^FDG-PET/CT have to be evaluated to inform policy decisions, these information gaps need to be filled with new methodological approaches.