# Discussion

## 1 Bladder Cancer

Evidence from three studies is available on the diagnostic performance of ^18^FDG-PET and ^18^FDG-PET/CT for bladder cancer. Data from a meta-analysis of two prospective studies totalling 88 participants showed that ^18^FDG-PET does not seem to be helpful in identifying the stage of the disease. The diagnostic accuracy of ^18^FDG-PET and ^18^FDG-PET/CT has not been evaluated for other clinical situations. These results are in agreement with findings reported by other researchers in this field. A recent review by Machtens et al179 evaluated the utility of ^18^FDG-PET as a diagnostic tool in malignant urological tumors of the small pelvis (e.g., prostate, testicular and bladder tumors). The authors found that, compared to other urologic malignancies, the value of ^18^FDG-PET in the imaging of bladder cancer has been investigated the least. No additional role for PET in comparison with conventional imaging in tumor detection and local staging was found for any of the indications. This review also included three studies published before 2003 that evaluated the diagnostic accuracy of ^18^FDG-PET in the imaging of bladder cancer and yielded similar conclusions. The methods used to identify the primary studies in the Machtens review were not stated and the results were likely affected by selection bias. The Duke report14 did not evaluate the evidence on the use of ^18^FDG-PET for bladder cancer and therefore, it is unknown whether further studies on this topic had been published prior to the search period that was covered in our report.

Only one study of moderate sample size and moderate quality evaluated the diagnostic thinking impact of ^18^FDG-PET on the treatment of bladder cancer and reported that 17 percent of the treatment decisions were changed after knowing the results of ^18^FDG-PET. Since the amount and quality of the evidence is limited, firm conclusions about the diagnostic thinking impact of ^18^FDG-PET in bladder cancer cannot be drawn. The American College of Radiology (ACR) has recently developed guidelines to evaluate the diagnostic and therapeutic value of a variety of imaging examinations for the pretreatment staging of invasive bladder cancer.180 Using a 9-point rating scale (1 = least appropriate, 9 = most appropriate), ^18^FDG-PET whole body scanning was rated below other diagnostic options, such as chest X-ray, CT urography, and pelvis MRI (rated 2, 9, 8, and 8 points, respectively).

## 2 Brain Cancer

Six studies provided evidence on the use of ^18^FDG-PET for brain cancer. We did not find studies that reported on the use of ^18^FDG-PET/CT for brain cancer. The majority of the studies evaluated the diagnostic accuracy of ^18^FDG-PET. ^18^FDG-PET does not seem to be highly discriminative in identifying the stage of the disease, and in distinguishing between necrosis and recurrences. The sensitivity and specificity values of the studies were modest and had wide confidence intervals, precluding firm conclusions about the diagnostic utility of ^18^FDG-PET for brain cancer. These results are in accordance with the findings reported for brain cancer in the Duke report. 14 Evidence on the diagnostic thinking impact and the economic value of ^18^FDG-PET and ^18^FDG-PET/CT for brain cancer is not available. The effects of ^18^FDG-PET as part of a management strategy on patient-centered outcomes continue to be scarcely evaluated. There is limited evidence from low quality studies identified here and in the Duke report that suggest that the best indication of ^18^FDG-PET seems to be differentiating between high and low grade gliomas. There is, however, no consensus regarding the utility of ^18^FDG-PET in predicting histological grading and survival of brain tumors.

## 3 Cervical Cancer

^18^FDG-PET and ^18^FDG-PET/CT have been evaluated for a variety of clinical indications in the assessment of patients with cervical cancer. These include 1) initial staging, 2) detection of recurrence, and 3) restaging, including planning for salvage therapy. There is evidence around the diagnostic accuracy for each of these indications, and also limited evidence for the diagnostic thinking impact. Only two studies provided evidence for the effects of ^18^FDG-PET on patient-centered outcomes and these addressed problems of detection of recurrence and restaging. There is no data on the cost effectiveness of either ^18^FDG-PET or ^18^FDG-PET/CT.

### Initial Staging

^18^FDG-PET or ^18^FDG-PET/CT has not been studied in women with early stage (FIGO 0 to Ia) cervical cancer who are treated with local therapy and do not usually undergo staging examinations.

Women with locally advanced carcinoma of the cervix (FIGO Stages Ib to IV) are treated with combined modality therapy consisting of radiation and chemotherapy. The usual practice prior to therapy is to stage with imaging tests (CT or MRI) of the abdomen and pelvis to guide treatment. A systematic review of the earlier literature7 suggested that the sensitivity of ^18^FDG-PET is superior to CT and/or MR imaging. PET imaging has the potential to identify additional sites of disease resulting in either more accurate delineation of radiation therapy fields and possibly improved patient-centered outcomes, or to identify patients with wide-spread disease who could then be spared futile combined modality therapy with its associated toxicity.

This current technology assessment identified that, when either ^18^FDG-PET or ^18^FDG-PET/CT were evaluated for staging purposes, the values for the positive and negative LRs were similar for both techniques. Results were also consistent when different reference standards were used and for both retrospective and prospective study designs. Significant results were reported for the positive LR, indicating that both techniques were useful to detect the stage of the disease. The results of the negative LR were not statistically significant. Only one study32 provided information indicating that improved diagnostic accuracy impacts positively on diagnostic thinking for initial staging. Although of moderate quality, the sample size of this prospective study was small at 42, with only 17 patients studied for staging of locally advanced disease. There are no studies evaluating the effect of ^18^FDG-PET or ^18^FDG-PET/CT on patient-centered outcomes. Additional high quality studies of the impact on diagnostic thinking and patient-centered outcomes, within the context of staging of locally advanced cervical cancer with ^18^FDG-PET/CT, are required.

### Detection of Recurrence and Restaging

Recurrent or persistent cervical cancer following radiation therapy may be treated with pelvic exenteration which is radical surgery removing the bladder, cervix, uterus, tubes and ovaries, para-cervical tissues and upper vagina. The surgery requires a team of surgeons from different specialties 6 to 12 hours of operative time. The surgery is only considered when there is no evidence of systemic or lymphatic spread of cancer. Restaging prior to surgery is currently performed with CT and pelvic MRI; however, the overall accuracy of detecting pelvic lymphadenopathy for CT scan is 72 percent (pooled sensitivity 0.47; 95% CI 0.21-0.73) and MRI 78 percent (pooled sensitivity 0.72; 95% CI 0.53-0.87). 181 Suboptimal restaging results in a relatively high rate of aborted exenterative procedures. Prospective studies of ^18^FDG-PET showed sensitivities of 50 percent to 100 percent in the detection of pelvic and abdominal lymphadenopathy and specificities of 94 percent to 100 percent; retrospective studies showed sensitivities of 80 percent to 96 percent and specificities of 76 percent to 100 percent. In both cases, the meta-analysis demonstrated statistically significant positive and negative LRs. The high sensitivity of ^18^FDG-PET and ^18^FDG-PET/CT has the potential to increase completion rates of radical surgery in women with recurrent or persistent cervical cancer through more appropriate selection of surgical candidates; this needs to be confirmed in future studies.

In summary, the use of ^18^FDG-PET or ^18^FDG-PET/CT shows promise to improve the care of patients with cervical cancer for both the staging of locally advanced disease and the detection and restaging of recurrent disease. The majority of studies in this area have provided evidence to support the value of FDG-PET or PET/CT for enhanced diagnostic accuracy. Future research should focus on generating more evidence for the impact on diagnostic thinking and patient-centered outcomes in order to confirm or refute the preliminary findings observed here. Cost studies are needed to clarify the relative costs and benefits of implementing FDG-PET in practice.

## 4 Kidney Cancer

Due to the potential problem of physiological excretion of ^18^FDG through the kidneys interfering with abnormal uptake of ^18^FDG within a primary renal tumor, the usefulness of ^18^FDG-PET has been explored mainly in the detection of local and distant metastases at initial staging and at restaging. There is some evidence to suggest that the accuracy of ^18^FDG-PET may be sufficient to support its use in the initial staging of renal cancer. When ^18^FDG-PET was compared against any reference standard in prospective studies, statistically significant results were obtained for both the positive and negative likelihood ratios. In retrospective studies, statistically significant results were only obtained for the negative likelihood ratio.

However the diagnostic thinking impact of this technology has been explore in only one study for patients with recurrent disease and in two studies for initial staging and detection of recurrence. All studies were retrospective and of moderate quality. The impact of the tests varied from 0 percent to 30 percent, the lowest impact being in restaging.

Because of the high sensitivities and specificities reported in prospective studies of diagnostic accuracy, the application of ^18^FDG-PET to at least initial staging of renal cancer seems to be worthy of additional study by well-designed prospective trials. There is insufficient evidence to support its widespread adoption at this time.

## 5 Ovarian Cancer

^18^FDG-PET and ^18^FDG-PET/CT have been evaluated for a variety of clinical indications in the assessment of patients with ovarian cancer. These include 1) primary diagnosis, 2) initial staging, 3) detection of recurrence and 3) restaging. There is evidence around the diagnostic accuracy for each of these indications, and also limited evidence for the diagnostic thinking impact. Only one study provided evidence for the effects of ^18^FDG-PET as part of a management strategy on patient-centered outcomes, and there is no data on the cost effectiveness of either ^18^FDG-PET or ^18^FDG-PET/CT for ovarian cancer. Most of the studies have evaluated the use of ^18^FDG-PET/CT.

^18^FDG-PET has not been studied in women with suspected ovarian cancer for primary diagnosic purposes. The evidence on the accuracy of ^18^FDG-PET/CT for the primary diagnosis of ovarian cancer is limited to two high-quality studies that reported individual sensitivity values ranging from 87% to 100%. Although the results are promising, no firm conclusions should be made based on these estimates and further studies should evaluate the value of ^18^FDG-PET/CT as part of the initial workup to diagnose ovarian cancer.

The evidence on the efficacy of ^18^FDG-PET and ^18^FDG-PET/CT for the initial staging of ovarian cancer is very limited and no firm conclusions can be made regarding their utility for this indication.

The clinical indication for which ^18^FDG-PET has been evaluated the most is for the detection of recurrences following treatment. Meta-analyses of the diagnostic accuracy of both ^18^FDG-PET and ^18^FDG-PET/CT showed a consistent, statistically significant effect in both the positive and negative LRs across a range of reference standards and study designs, providing evidence to support the usefulness of ^18^FDG-PET and ^18^FDG-PET/CT in detecting ovarian cancer recurrences. Only one comparison did not yield a statistically significant positive LR, however this result could be attributed to smaller numbers of studies in the analysis and smaller samples.

Previous evaluations of the earlier literature on the diagnostic performance of ^18^FDG-PET for ovarian cancer7,14 suggested that ^18^FDG-PET is less useful for detecting microscopic residual ovarian cancer, but has fair sensitivity for detecting disease recurrence. This current technology assessment identified that, when either ^18^FDG-PET or ^18^FDG-PET/CT were evaluated for the detection of recurrences, the values for the pooled positive and negative LRs were similar for both techniques.

The results of this technology report indicate that ^18^FDG-PET, especially when combined with CT, is a potentially useful tool for detecting recurrent ovarian tumors. These results agree with the findings reported by other researchers that have synthesized the evidence on the clinical efficacy of ^18^FDG-PET or ^18^FDG-PET/CT. 182,183 Particularly, the American College of Radiology (ACR) has recently developed evidence-based guidelines to evaluate the diagnostic and therapeutic value of a variety of imaging examinations for ovarian cancer. 183 After an analysis of the current literature and expert panel consensus, ACR recommendations for the staging of ovarian cancer do not include ^18^FDG-PET/CT, and priority is given to the use of abdominal and pelvic CT and CA–125. Alternatively, ^18^FDG-PET/CT is considered to rule out recurrent ovarian cancer along with these two options and in some instances, it can substitute for CT.

The evidence on the diagnostic thinking impact of PET is limited to integrated ^18^FDG-PET/CT imaging for assessing recurrence of ovarian cancer. The five studies consistently demonstrated that ^18^FDG-PET/CT altered management plans in an important proportion of patients and confirmed the results of previous evaluations. 14 Only one study of poor quality examined the effect of ^18^FDG-PET/CT on patient-centered outcomes and prognosis, and prohibited any definitive conclusions about the value of ^18^FDG-PET/CT as part of a management strategy.

## 6 Pancreatic Cancer

Seventeen studies evaluated the diagnostic accuracy of ^18^FDG-PET or ^18^FDG-PET/CT. The majority of studies are on ^18^FDG-PET but some of them have evaluated ^18^FDG-PET/CT. The findings were consistently significant, suggesting that both ^18^FDG-PET and ^18^FDG-PET/CT are useful in diagnosing and establishing initial stage of the disease. However, the pooled results are, for the most part, heterogeneous; therefore, the magnitude of the effect is uncertain. Further, there is no clear evidence for the choice of ^18^FDG-PET v. ^18^FDG-PET/CT, since the observed heterogeneity indicates considerable uncertainty in these estimates. We found that when ^18^FDG-PET was evaluated for primary diagnostic purposes, the positive LR was slightly better for ruling in the disease, but the negative LR remained almost the same.

A review by the Blue Cross Blue Shield Association184 compared the use of ^18^FDG-PET with the use of conventional diagnostic workup (i.e., CT, MRI, and ultrasonography) and ^201^Tl SPECT. The review concluded that ^18^FDG-PET helps to differentiate benign from malignant lesions in patients with suspected pancreatic malignancies.

A review by Higashi et al185 of the literature published from 1999 to 2003 on the utility of ^18^FDG-PET for the diagnosis of pancreatic cancer concluded that ^18^FDG-PET can effectively differentiate pancreatic cancer from benign lesions with a high degree of accuracy. A systematic review by Orlando et al8 evaluated the evidence published between 1966 and 2003 about the diagnostic accuracy of ^18^FDG-PET/CT compared with CT alone for the detection of pancreatic cancer. The authors found that adding ^18^FDG-PET/CT to the diagnostic workup can be of benefit in detecting pancreatic malignancies depending of the pretest probability of the patient. These conclusions are supported by the findings of the Duke report, 14 in which ^18^FDG-PET sensitivity and specificity were found to be slightly better than CT alone. Evidence on the use of ^18^FDG-PET for recurrences and staging is derived from individual study data and therefore, firm conclusions about the utility of ^18^FDG-PET for these indications cannot be made.

There is some evidence on the diagnostic thinking impact of ^18^FDG-PET and ^18^FDG-PET/CT that indicates that the management plan is altered in an important number of patients (up to 69 percent), more often resulting in a conservative course of management thus avoiding unnecessary surgery. The review by the Blue Cross Blue Shield Association184 also addressed the question about how ^18^FDG-PET can alter diagnosis and management decisions; however, no firm conclusions were made because results of primary studies differed considerably. The review by Higashi et al185 concluded that ^18^FDG-PET is useful and cost-beneficial in the preoperative staging of pancreatic cancer. According to the authors, ^18^FDG-PET may be able to detect unexpected distant metastases in about 40% of the cases. Only one study reported on the effects of ^18^FDG-PET on patient-centered outcomes and there is limited evidence that ^18^FDG-PET can improve time to disease progression.

Finally, one study conducted a cost-minimization analysis on the use of ^18^FDG-PET/CT for pancreatic cancer. The analysis, however, is insufficient to demonstrate changes in costs relative to changes in clinical effects due to the implementation of ^18^FDG-PET/CT in the diagnostic workup of pancreatic cancer. The study does not provide a common diagnostic efficacy denominator for ^18^FDG-PET/CT, therefore precluding a cost-effectiveness analysis.

## 7 Prostate Cancer

The studies identified for analysis in this technology assessment addressed only the detection of recurrence in patients with an increased PSA following primary therapy for prostate cancer. No study addressed the diagnosis or staging of disease. Due to heterogeneity across studies in terms of study design, type of PET and indications for its use, no pooled estimate of the accuracy of ^18^FDG-PET could be obtained. The impact of ^18^FDG-PET on diagnostic thinking or patient-centered outcomes was not assessed in any studies. Furthermore, there is no data available describing the use of ^18^FDG-PET/CT technology, which might be expected to improve diagnostic accuracy in pelvic imaging compared to ^18^FDG-PET, since false positive results might occur due to urinary excretion of ^18^FDG.

PSA relapse after primary therapy for prostate cancer is a common clinical problem. Frequently the PSA begins to increase before recurrent disease can be localized clinically or by imaging studies. The average time between PSA relapse and the clinical presentation of metastases is eight years. 186 There is controversy regarding when treatment should be initiated, and which treatment modality is most appropriate. 187 At present, the need for a highly sensitive test to restage disease and aid in the prescription of therapy has not been confirmed. Furthermore, the role of ^18^FDG-PET or ^18^FDG-PET/CT as compared to existing anatomical imaging has not been fully characterized. There is currently insufficient data to recommend the introduction of ^18^FDG-PET or ^18^FDG-PET/CT imaging for this indication.

## 8 Small Cell Lung Cancer

There is no evidence to support the role of ^18^FDG-PET or ^18^FDG-PET/CT in the diagnosis of SCLC and no cost-effectiveness data is available for this tumour for any indication. However, there is preliminary evidence from three cohort studies of moderate quality supporting the technique’s use in staging and restaging.

The current staging system in SCLC reflects treatment algorithms that recommend thoracic radiation only in patients with limited stage disease, where all known disease can be encompassed by radiation. Meta-analyses have shown that radiation under these circumstances results in a modest improvement in survival. 188 The correct identification of this subgroup of patients, with accurate delineation of radiation fields, might be expected to improve outcomes.

Information on the specificity of ^18^FDG-PET or ^18^FDG-PET/CT was not available; therefore pooled estimates of the positive and negative likelihood ratios could not be obtained. However, the sensitivities of the ^18^FDG-PET and ^18^FDG-PET/CT were consistently high across studies. Studies suggest that staging or restaging with FDG-PET can improve on the accuracy of conventional staging investigations such as CT, MRI and radionuclide bone scans. 112,113,117 The data suggests that between 5 percent and 10 percent of patients with SCLC may be upstaged to extensive stage disease112-114,116,117,119 and a small number of patients with extensive stage disease may be downstaged to limited stage112,114,117 based on ^18^FDG-PET or ^18^FDG-PET/CT findings. These findings have potential to alter the decision about whether or not to use radiation treatment. In addition, the radiation treatment plan may be influenced in 15 percent to 30 percent of patients. 112,113,117,119 These results would suggest that FDG-PET should be a part of the staging investigations of SCLC.

These data are limited in that the studies are generally small and subject to bias. Nevertheless there is consistency in the findings that FDG-PET appears more accurate than conventional staging investigations for SCLC. There is a lack of information about patient-centered outcomes from any of the studies to date. None of the studies report on whether treatment changes directed by staging with FDG-PET changes the patient-centered outcomes for patients with SCLC. Future research should attempt to address this issue.

## 9 Testicular Cancer

The recent evidence for ^18^FDG-PET in testicular cancer is very limited and inconclusive. Four studies of moderate quality evaluated the diagnostic accuracy of ^18^FDG-PET for testicular cancer. ^18^FDG-PET/CT has not been evaluated for this condition. The clinical indications that were evaluated included initial staging, restaging and recurrences; however, a pooled analyzes of the data was precluded due to the limited number of studies.

Previous evaluation have found direct and consistent evidence about a higher sensitivity and specificity of ^18^FDG-PET compared to CT for the initial staging of patients with germ cell tumors. 14 However, the clinical relevance of these results have been questioned due to heterogeneity in the clinical populations evaluated. A recent narrative review by Machtens et al179 has discussed the utility of ^18^FDG-PET as a diagnostic tool in malignant urological tumors of the small pelvis (e.g., prostate, testicular and bladder tumors). The authors found no additional role for PET in comparison with conventional imaging in tumor detection and local staging for testicular cancer; however, they suggested that the use of FDG-PET can be considered in the restaging of seminomatous germ cell tumors after chemotherapy. This review did not use a systematic approach in the selection and evaluation of the primary studies and therefore, a variety of bias may affect the validity of the results and conclusions.

One small retrospective study of moderate methodological quality evaluated the physician decision-making impact when ^18^FDG-PET imaging is used in the assessment of the recurrence of testicular cancer. The management plan was changed in only a small proportion of the patients, suggesting that ^18^FDG-PET imaging had minimal effect on subsequent treatment decisions. Evidence from larger, prospective studies of higher quality is needed before conclusions can be made regarding the impact of ^18^FDG-PET imaging on patient management for testicular cancer.

Our findings agree with those reported by a synthesis of the evidence reported by the American College of Radiology (ACR) on the diagnostic and therapeutic value of a variety of imaging examinations for the staging of testicular malignancies. 189 Using a 9-point rating scale (1 = least appropriate, 9 = most appropriate), ^18^FDG-PET whole body scanning was rated below other diagnostic options, such as chest X-ray, abdomen and pelvis CT, chest CT, and abdomen and pelvis MRI (rated 4, 9, 8, 7, and 5 points, respectively). ^18^FDG-PET is likely best suited for following up recurrent disease and differentiating residual nonseminomatous tumors from mature teratoma.

Finally, none of the studies evaluated the effects of ^18^FDG-PET or ^18^FDG-PET/CT as part of a management strategy on patient-centered outcomes. There were no economic evaluations on the use of ^18^FDG-PET and therefore, no firm conclusions on the clinical and economic impact of ^18^FDG-PET or ^18^FDG-PET/CT can be made. There is no evidence that the preliminary results provided by a limited number of small primary studies can be translated into meaningful advances in the management of patients with testicular malignancies. Further well-designed prospective studies are required to assess the value of ^18^FDG-PET and ^18^FDG-PET/CT in areas that remain unevaluated, such as clinical management and treatment response.