# Results

## Search Results

Overall, the literature search (electronic and reference lists) resulted in the identification of 12,568 citations of which 7,173 were duplicates. After screening titles and abstracts (5,395 citations), the full-texts of 502 potentially relevant articles were retrieved and evaluated for inclusion. The application of the selection criteria to the 502 articles resulted in 393 articles being excluded, while 109 articles were relevant to the questions addressed in this review. Figure 1 outlines study retrieval and selection.

Figure 1 Flow Diagram for Study Retrieval and Selection for the Technology Report

* One study provided data for both cervical and ovarian cancer

Figure 1 is a flow diagram that outlines study retrieval and selection process. It consists of boxes with text that describes the study selection process from the total number of citations retrieved from the literature searches to the number of studies that satisfied the inclusion criteria of the report. This figure is described further in page 21, Section of •Search Results• as follows: •The literature search (electronic and reference lists) resulted in the identification of 12,568 citations. After screening titles and abstracts (5,395 citations), the full-texts of 502 potentially relevant articles were retrieved and evaluated for inclusion. The application of the selection criteria to the 502 articles resulted in 390 articles being excluded, while 112 studies were relevant to the questions addressed in this review. The primary reasons for exclusion of studies were as follows: (1) the study did not report on any of the nine types of cancer (n = 192), (2) the study did not evaluate the questions of interest (n = 93), (3) the study reported on less than 12 participants (n = 31), (4) the study did not use a matched design (n = 28), (5) the study did not evaluate 18FDG-PET or 18FDG-PET/CT (n = 12), (6) the study was not primary research (n = 13), and (7) the study was published in a language other than English (n=21)

The primary reasons for exclusion of studies were as follows: (1) the study did not report on any of the nine types of cancer (n = 192), (2) the study did not evaluate the questions of interest (n = 95), (3) the study reported on less than 12 participants (n = 32), (4) the study did not use a matched design (n = 28), (5) the study did not evaluate ^18^FDG-PET or ^18^FDG-PET/CT (n = 12), (6) the study was not primary research (n = 13), and (7) the study was published in a language other than English (n = 21) (Appendix C).

## 1 Bladder Cancer

### 1.1 Background

Approximately five to ten percent of all malignancies in men are bladder cancer. Throughout the United States and Europe it is the fourth most common cancer diagnosed. 131 It is also the most common cancer of the urinary tract. 132 Men are diagnosed with bladder cancer three to four times more frequently than women. 131 It is estimated that 68,810 new cases of bladder cancer will be diagnosed in the United States in 2008. Of these cases: 51,230 will be men and 17,580 will be women. Furthermore, approximately 14,100 deaths will occur as a result of this malignancy: 9,950 men and 4,150 women. 133 African-Americans are at half the risk of Caucasian-Americans in developing bladder cancer, but African-Americans have a poorer overall survival. 131 Bladder cancer tends to present in an older age group, with the median age of diagnosis at 73 years of age. 133

Bladder cancer is a heterogeneous disease and its natural history varies. 131 At one end of the spectrum bladder cancer may be of low-grade with slow progression, where on the other end it may be high-grade, highly malignant with significant progression and result in death. 131 The most frequently diagnosed form of bladder cancer (approximately 75 percent) is superficial disease contained in the mucosal and submucosal layers. The remaining patients are diagnosed with muscle-invasive disease, which extends outside the bladder. Bladder cancer patients have shown a 5-year cause-specific survival of more than 95 percent; however, recurrence occurs in more than 50 percent of patients and up to 20 percent develop invasive or metastatic disease.134

The most frequent warning sign is painless hematuria, which occurs in 85 percent of patients. Microscopic hematuria may also be present and should be screened for in high-risk patients over the age of 50. Bladder irritability, urinary frequency, urgency and dysuria are common. Patients with advanced disease may experience weight loss and abdominal or bone pain.131

In order to plan appropriate patient care, accurate staging must be completed. 131 Bladder cancer is staged using the TNMS (tumor, node, metastasis staging) system, approved by the Union International Contre le Cancer (UICC) in 2002 (Table 5). Tumors identified as “Ta” are considered noninvasive papillary carcinoma, whereas “Tis” refers to carcinoma in situ. 132 Any involvement in the lymph nodes is taken into consideration when staging bladder cancer, as is distant metastasis.

Table 5 Bladder cancer stages

Stage | Description
T1 | - subepithelial connective tissue invaded, not muscularis propria131; - diagnosis difficult, variable prognosis132
T2a | - <50% of the depth of muscularis propria invaded131
T2b | - >50% of the depth of muscularis propria invaded131
T3a | - perivesical tissue invaded (microscopic) 132
T3b | - perivesical tissue invaded (macroscopic) 132
T4a | - tumor expansion to prostrate, uterus and vagina132
T4b | - tumor expansion to pelvic wall, abdominal wall132

Early detection of cancer can help improve survival, which is the main goal of screening. Usually only patients at elevated risk are screened on a regular basis. Ideal screening methods are noninvasive, inexpensive and are highly sensitive and accurate. Tests used to identify bladder cancer include hematuria testing, cystoscopy, bladder imaging, urine cytology and bladder tumor markers. 131 Diagnosis frequently depends on cystoscopic and histologic evaluation of resected tissue. 132 A high rate of incorrectly classified high-grade Ta tumors (grade 3 tumors or higher) has been noted. 135

The standard method of detection of bladder cancer is cystoscopy. Cystoscopy identifies most superficial disease; however, it is not always successful at detecting small or flat lesions. Additionally, cytoscopy is an invasive procedure. The use of a flexible fiberoscopy is preferred as it is less invasive and provides a clear picture of the bladder interior. Fluorescence endoscopy may also be used for viewing the intravesical area and is reported to have high sensitivity and reasonable specificity, especially for the small or flat lesions frequently missed by conventional cystoscopy. 134 Intravenous urography detects large tumors in the bladder, the upper urinary tract and defects in the kidney. It is unclear if this method of screening is useful as the detection of significant findings is low. 132 Often a combination of methods are required for an accurate diagnosis of small or flat lesions. 135

Urine cytology is considered a good screening method for high-grade cancers. 131 Sensitivity and specificity are both greater than 90 percent, but it frequently does not detect low-grade papillary tumors. A positive result from urinary cytology indicates a tumor is present in the urinary tract, but does not pinpoint where. 132 Cytology is inexpensive and minimally inconvenient to the patient. 131 There is uncertainty about whether cytology should be performed from a voided urine sample or from a bladder wash sample. Histology from the bladder biopsy is used to make the final diagnosis. 135

^18^FDG-PET can be useful for detecting recurrent tumors in the pelvis, distinguishing local recurrent disease from postsurgical or postirradation fibrosis or necrosis and identifying metastases. However, there is some questions about the value of PET for the management of low-grade or noninvasive tumors due to the excretion of ^18^FDG by the kidneys and interference with imaging techniques by streak artifacts. Researchers have attempted to limit the amount of ^18^FDG released in the bladder.

The first treatment for superficial bladder cancer is transurethral resection (TUR) of the tumor. 134 Establishing the correct diagnosis and removing all visible lesions is the aim of TUR. Small tumors may be resected together, while larger tumors need to be resected individually. Frequently bladder tumors are multifocal and therefore there is a risk that tumors may remain after initial TUR. Additionally, tumors may be understaged. 132 A second TUR reduces understaging and the risk of residual disease. 135 Recurrence and progression-free survival may be improved by a second TUR. 132 Followup treatment for TUR is intravesical chemotherapy and it reduces the risk of reoccurrence. Efficacy of chemotherapy agents appears to be similar. In the case of muscle invasive cancer, radical cystectomy is performed. Immunotherapy with Bacillus Clamette-Guérin (BCG) is frequently used after TUR when the disease is confined to the mucosa or submocosa. While the exact mechanism of action is unknown, BCG forms a standard component of treatment for carcinoma in situ. The aim is to eradicate and prevent recurrence of superficial bladder cancer. 134

### 1.2 Importance of Key Questions in the Clinical Management of Bladder Cancer

The most important factors in survival from bladder cancer are the stage and the tumor histological grade at diagnosis. Prognosis of bladder cancer is highly dependent on the depth of tumor penetration into the bladder wall. Errors in clinical staging are more likely as the tumor becomes more invasive. Problematic areas for diagnosis and staging of bladder cancer include determination of deep bladder wall invasion and presence of lymph-node metastases. Therefore, accurate staging is pivotal in optimal therapy planning and in avoiding radical surgery in patients with bladder cancer. Some standard imaging methods (e.g., abdominal ultrasonography, CT and MRI) may not provide an accurate basis for therapeutic decisions. For example, tumor involvement is not necessarily detected by changes in the shape or texture of an affected lymph node through CT and MRI. The clinical interpretation of very small lymph nodes on CT and MRI is also problematic as the presence of enlarged regional lymph nodes are not always indicative of metastasis but rather may be reactive to certain procedures such as transurethral biopsy. Procedures such as CT-guided fine-needle aspiration biopsy can increase the overall staging accuracy but they are subject to sampling errors. ^18^FDG-PET can be a valuable test for the diagnosis of bladder cancer; however, the evidence about the accuracy and impact of ^18^FDG-PET on therapeutic decisions and outcomes for bladder cancer patients is scarce. This is partly due to difficulties in interpreting the ^18^FDG-PET images in the pelvis because ^18^FDG is excreted by the kidneys and accumulated in ureters and the urinary bladder.

### 1.3 Results

Three studies23-25 provided evidence on the use of ^18^FDG-PET or ^18^FDG-PET/CT for bladder cancer. Each of the three studies evaluated the diagnostic accuracy of ^18^FDG-PET23-25 or ^18^FDG-PET/CT,24 and one study24 reported on the diagnostic thinking impact. None of the studies evaluated the effects of ^18^FDG-PET or ^18^FDG-PET/CT as part of a management strategy on patient-centered outcomes. No economic evaluations of ^18^FDG-PET or ^18^FDG-PET/CT for bladder cancer were identified. Characteristics of the populations, conditions of ^18^FDG-PET administration, interpretation of results and methodological quality of the studies are summarized in Appendices D to J.

#### 1.3.1 Diagnostic accuracy of ^18^FDG-PET and ^18^FDG-PET/CT in bladder cancer

##### Characteristics of the studies

Three studies (two prospective, 23,25 one retrospective24) evaluated the diagnostic accuracy of ^18^FDG-PET23-25 and ^18^FDG-PET/CT24 on bladder cancer. Two studies used ^18^FDG-PET for initial staging23,25 and one used ^18^FDG-PET/CT for both staging and restaging purposes. 24

The studies contained a total of 136 patients with sample sizes ranging from 35 to 55 participants. Participant ages ranged from 33 to 86 years. One study reported the distribution by stage of cancer: clinical stage (CS) I = 16 percent, CS II = 47 percent, CS III = 31 percent and CS IV = 6 percent. 23 ^18^FDG-PET was compared to a reference standard that varied across the studies. In two studies the reference standard was either histology/biopsy or clinical followup. 23,24 One study established the final diagnosis of all patients using histology/biopsy. 25 One study reported the mean time between last treatment and ^18^FDG-PET as 37 days. 23 Two studies used a fixed dose of ^18^FDG (15 MCi25 and 555 MBq24); one study used a weight-based dose (6.5 MBq/kg). 23 The time between injection and PET scan was 60 minutes23,24 and 20 minutes. 25 Patients fasted for six hours. 23,24 Two studies23,24 measured glucose levels before administration of ^18^FDG-PET; the maximum glucose level that was allowed was 120 mg/dL. Methods of interpretation of the images were qualitative in one study23 and both qualitative and quantitative in a second. 24 Scans were interpreted qualitatively using visual analysis. 23,24 One study24 reported using SUV but the criterion for abnormality was not reported.

##### Comparisons

Comparisons for which data were considered for meta-analysis are summarized in Table 6. Pooled data were obtained to evaluate the accuracy of ^18^FDG-PET for the staging of bladder cancer. Individual study data are summarized in Appendix D.

Table 6 Summary of comparisons considered for meta-analyses of the accuracy of ^18^FDG-PET for bladder cancer

Indication | Studies | Design | Type of PET | Reference standard | Meta-analysis
Staging | Drieskens 2005^23^ | P | FDG-PET | Histology/biopsy or clinical followup | 1. FDG-PET v. any reference standard (P studies) 23,25
Staging | Liu 2003^25^ | P | FDG-PET | Histology/biopsy | 1. FDG-PET v. any reference standard (P studies) 23,25
Staging and restaging | Jadvar 2008^24^ | R | FDG-PET and FDG-PET/CT | Histology/biopsy or clinical followup | No

CT = computed tomography; FDG = fluorodeoxyglucose F18; P = prospective; PET = positron emission tomography; R = retrospective

###### 1 ^18^FDG-PET for the staging of bladder cancer

Reference standard: any; prospective studies. Two prospective studies23,25 totaling 88 participants provided data for a meta-analysis of the accuracy of ^18^FDG-PET compared to any reference standard for the staging of bladder cancer. Individual 2x2 table results are presented in Figure 2. Sensitivity values in individual studies were 53 percent23 and 77 percent. 25 Specificity values were 72 percent23 and 94 percent. 25

Figure 2 Results from 2x2 tables of individual prospective studies of ^18^FDG-PET v. any reference standard for the staging of bladder cancer

Figure 2 is a forest plot-type diagram that reports the sensitivity and specificity of 18FDG-PET versus any reference standard for the staging of bladder cancer. The figure is described in the section of •18FDG-PET for the staging of bladder cancer. Reference standard: any; prospective studies. (page 27) as follows: •Two prospective studies totally 88 participants provided data for meta-analysis of the accuracy of 18FDG-PET compared to any reference standard for the staging of bladder cancer. Sensitivity values in the individual studies were 53% (Drieskens) and 77% (Liu). Specificity values were 72% (Drieskens) and 94% (Liu).

We found that ^18^FDG-PET had a pooled positive LR of 4.68 (95% CI = 0.65, 33.90) and a pooled negative LR of 0.43 (95% CI = 0.15, 1.19) to accurately detect the stage of bladder cancer (Figures 3 and 4). Neither the positive nor negative LRs were statistically significant, as the 95% CIs included one. Therefore, ^18^FDG-PET does not seem to be helpful in identifying the stage of the disease. There was considerable heterogeneity in the positive (p = 0.01; I^2^ = 84 percent) and negative (p = 0.07, I^2^ = 69 percent) LRs across the studies. Liu25 reported statistically significant results for both the positive and negative LRs, whereas results in Drieskens23 were not statistically significant. It is hard to draw definite conclusions based on the results of two small studies that provide heterogeneous results for the pooled estimates of the accuracy of ^18^FDG-PET to identify the stage of bladder cancer.

Figure 3 Meta-analysis of the positive likelihood ratio of ^18^FDG-PET v. any reference standard for the staging of bladder cancer (prospective studies)

Figure 3 is a meta-graph depicting the positive likelihood ratio of 18FDG-PET versus any reference standard for the staging of bladder cancer. The figure is discussed in the section of •18FDG-PET for the staging of bladder cancer. Reference standard: any; prospective studies. (page 27-8). Two studies contributed to data from 88 participants. The pooled positive likelihood ratio to rule in the stage of bladder cancer was 4.68 (95% confidence interval 0.65, 33.90). This ratio was not statistically significant. Considerable heterogeneity (p = 0.01, I2 = 84 percent) was present.

Figure 4 Meta-analysis of the negative likelihood ratio of ^18^FDG-PET v. any reference standard for the staging of bladder cancer (prospective studies)

Figure 4 is a meta-graph depicting the negative likelihood ratio of 18FDG-PET versus any reference standard for the staging of bladder cancer. The figure is discussed in the section of •18FDG-PET for the staging of bladder cancer. Reference standard: any; prospective studies. (page 27-28). Two studies contributed to data from 88 participants. The pooled negative likelihood ratio to rule out the stage of bladder cancer was 0.43 (95% confidence interval 0.15, 1.19). This ratio was not statistically significant. Considerable heterogeneity (p = 0.07, I2 = 69 percent) was present.

Figure 5 shows the estimates of sensitivity and 1-specificity plotted in ROC space for ^18^FDG-PET v. any reference standard to identify the stage of bladder cancer.

Figure 5 Summary ROC plot of ^18^FDG-PET v. any reference standard for the staging of bladder cancer (prospective studies)

Figure 5 is a summary ROC plot that describes the paired estimates of sensitivity and 1-specificity for the included studies of 18FDG-PET versus any reference standard for the staging of bladder cancer (prospective). The curve appears near the top left hand corner.

##### Summary of the results

A meta-analysis was calculated to evaluate the accuracy of ^18^FDG-PET to identify the stage of bladder cancer. The pooled LRs were not statistically significant and therefore, ^18^FDG-PET does not seem to be helpful for detecting the stage of the disease (Table 7). Heterogeneity across the studies was significant, precluding us from making strong inferences from the pooled overall results.

Table 7 Results of meta-analysis of the accuracy of ^18^FDG-PET for bladder cancer

PET Purpose | Type | Design | Reference standard | Studies | N | Effect estimate M-H, Random, 95% CI
Staging | FDG-PET | P | Any reference standard | 2 | 88 | PLR = 4.68 [0.65, 33.90]
Staging | FDG-PET | P | Any reference standard | 2 | 88 | NLR = 0.43 [0.15, 1.19]

CI = confidence interval; FDG = fluorodeoxyglucose F18; M-H = Mantel Hantzel; NLR = negative likelihood ratio; P = prospective; PET = positron emission tomography; PLR = positive likelihood ratio

#### 1.3.2 Diagnostic thinking impact of ^18^FDG-PET and ^18^FDG-PET/CT on physician decision making with respect to diagnosis and management strategy for patients with bladder cancer

One study evaluated the diagnostic thinking impact of ^18^FDG-PET ^18^FDG-PET and ^18^FDG-PET/CT on the treatment of bladder cancer. A retrospective study by Jadvar et al. 24 evaluated the influence of ^18^FDG-PET and ^18^FDG-PET/CT on the management of patients who had been previously treated for transitional cell carcinoma and who were under evaluation for staging and restaging. Both ^18^FDG-PET and ^18^FDG-PET/CT were used in this study; however, the results were not separated by the mode of imaging used. The population enrolled was of moderate size (N = 35) and encompassed a wide age range (39-86 years). The subjects were predominately male (71 percent), nondiabetic, with a history of bladder transitional cell carcinoma at initial stages (B2 and C). ^18^FDG-PET was performed in 17 patients and ^18^FDG-PET/CT in 18 patients, but mixed results were presented from the two devices.

The diagnostic thinking impact of ^18^FDG-PET and ^18^FDG-PET/CT was reported as changes in the clinical management of patients. Overall, 17 percent of the patients in the study had their treatment course altered as a result of the ^18^FDG-PET or and ^18^FDG-PET/CT imaging analysis. Five patients underwent additional courses of chemotherapy and one patient was under a regime of observation. While the remaining 29 patients did not have their care significantly altered by ^18^FDG-PET or ^18^FDG-PET/CT, the authors noted that there was more precise localization of hypermetabolic disease. The authors concluded that combined ^18^FDG-PET and CT diagnostic information was useful in detecting, localizing and characterizing the extent of metastatic disease.

Overall, the quality of the study was assessed as moderate using the SIGN Methodology Checklist tool. The level of evidence was graded as C (several methodological flaws). Significant issues with the quality of this study included the unblinded interpretation of the ^18^FDG-PET and ^18^FDG-PET/CT and the use of multiple modalities to verify the presence of disease (e.g., histology, serial imaging). Additionally, the selection criteria for the patients in this retrospective analysis were not specified, raising the possibility of selection bias. Finally, as there was no clearly defined time period between the ^18^FDG-PET and ^18^FDG-PET/CT and the reference standard, disease progression may have occurred between the assessment of the ^18^FDG-PET/^18^FDG-PET/CT and the final designation of disease status.

Because of the relatively small number of patients included in the Jadvar et al. 24 study, further studies are necessary to assess the role of ^18^FDG-PET or and ^18^FDG-PET/CT to make clinical management decisions for bladder cancer patients. Table 8 provides a summary of the main findings and the types of bias that affected the evidence on the diagnostic thinking impact of ^18^FDG-PET and ^18^FDG-PET/CT on bladder cancer.

Table 8 Main findings and types of bias that affected the evidence on the diagnostic thinking impact of ^18^FDG-PET and ^18^FDG-PET/CT for bladder cancer

Study | Results of FDG-PET imaging on patient diagnosis and treatment | Types of bias
Jadvar H, 2008^24^ Study type: Retrospective | Management decision: Treatment Changes in clinical management after PET/CT: 6/35 (17%): Additional chemotherapy: n = 5 Wait-and-watch regimen: n = 1 | Selection bias (unclear) Disease progression bias (unclear) Verification bias (>1 RS) Review bias (PET, unblinded; RS unclear if blinded)

CT = computed tomography; FDG = fluorodeoxyglucose F18; PET = positron emission tomography; RS = reference standard

## 2 Brain Cancer

### 2.1 Background

An estimated 21,810 new cases of brain cancer will be diagnosed in the United States in 2008 and 13,070 patients will die from the disease. 133 Primary brain tumors represent a small number of all primary malignant cancers diagnosed, approximately 1.35 percent. Brain cancer as a result of metastases is more common. 136 Brain cancer incidence has increased over time; however, this is largely due to improvements in diagnostic tools, health care, changes in the treatment of elderly patients and changes to the classification of brain tumors. 137 The incidence of brain cancer between 2001 and 2005 was 6.0/100,000^133^ in the United States. Caucasians experience certain types of brain tumors (glioma and germ cell tumors) twice as often as African-Americans. In the United States, incidence rates vary from 9.6/100,000 in Virginia to 21.9/100,000 in Colorado. The high rates of brain cancer detected may be linked to greater access to health care and better health care. 137

Malignant brain tumors encompass a wide range of neoplasms. 136 Patients who are diagnosed with glioblastoma tumors tend to have the shortest survival time of brain cancer patients (less than one third of patients survive one year); similarly, older patients tend to have shorter survival time. 137 The median age for diagnosis of brain cancer is 56 years, while the median age at death is 64 years. 133 According to numbers recorded between 1998 and 2003, 37.7 percent of patients diagnosed with a primary malignant brain tumor survived for 2 years and 30.2 percent survived for 5 years. 137 Primary brain malignancies tend to remain local and rarely spread outside the CNS. 136

Brain tumors may present differently depending on the location of the lesion, rate of growth and histology. 136 In the initial stages of the disease most symptoms are focalized. As tumor size increases, more generalized symptoms occur. 138 Approximately 50 percent of patients will present with headache, 136 which can last for six months or more. Increased intracranial pressure may cause nausea and vomiting and in patients with low-grade gliomas, seizures are common. 136 Cognitive dysfunction may also occur, which is demonstrated by changes in memory, attention, language use and personality. 138

Patient prognosis is linked to a number of factors, as are treatment strategies. 137 Increased survival is associated with patient age less than 60, presence of seizures, frontal lobe tumors, low-grade tumors, no tumor necrosis, limited tumor activity, Karnofsky Performance Status scores greater than 70 and total or near-total resection. The World Health Organization (WHO) classifies brain tumors according to type of cell and histological appearance. 138 The major histological groups are: neuroepithelial tissue or gliomas, tumors of the meninges, germ cell tumors and tumors of sellar regions. 137 More than 80 percent of primary brain tumors are gliomas, tumors of the meninges make up much of the rest. 138

Diagnosis starts with a complete medical history, physical examination and a careful neurological assessment. 136 In addition, funduscopy and a focused neurologic examination are performed. Appropriate brain imaging is required followed by histopathology to confirm diagnosis. 138

MRI is used for the initial screening of brain tumors. It produces higher resolution images and can access more areas of the brain than CT scans and is used for neurosurgical planning and risk assessment. 138 To distinguish infiltrative brain tumors from nonneoplastic conditions, high-grade from low-grade tumors, and primary tumors from metastastic tumors, magnetic resonance spectroscopy (MRS) may be used. 136

Biochemical and metabolic information about tumors and the brain can be determined by MRS. The diagnostic standard is still tissue biopsy. More recently developed stereotactic biopsy techniques are minimally invasive, with decreased morbidity and mortality relative to traditional neurosurgery. Stereotactic biopsy should be obtained to help confirm diagnosis of low-grade gliomas. MRI, MRS and ^18^FDG-PET assist in tumor localization for biopsy. Testing for biomarkers may also assist in diagnosis, treatment planning and predicting prognosis. 136

If it is possible to perform a complete resection, surgery is the treatment of choice; 138 there are no clear guidelines on degree or timing of the resection. 136 The decision is based on tumor location, extent, histopathology and comorbid conditions. In the case of high-grade gliomas, a near to total resection aims to decrease tumor burden, by lowering intracranial pressure and improving survival. The patient should be screened for residual tumors within the first three days after surgery. Radiation, chemotherapy or a combination of both frequently follow surgery. 138 As of yet, it is unclear whether it is best to immediately proceed with postoperative radiotherapy, or whether the patient should be observed before proceeding with additional treatment. Early radiation therapy may improve survival times, but it can also lead to radiation-related neurotoxicity. Older patients, whose risk of recurrence is high, may be offered radiotherapy immediately after surgery. 136 Combined chemo- and radiotherapy help improve survival over standard radiation. Patients who are not candidates for surgery or chemotherapy should be considered for palliative care. 138

### 2.2 Importance of Key Questions in the Clinical Management of Brain Cancer

Imaging of brain tumors with ^18^FDG was the first oncologic application of PET for tumor detection, grading of cerebral tumors and assessment of peritumor or remote metabolic alterations. The application of ^18^FDG-PET for tumor imaging of the brain is based on increased glycolysis in neoplastic cells. ^18^FDG-PET could be useful to diagnose and grade gliomas and differentiate between tumor recurrence and radiation necrosis. It may be also useful to predict tumor response to chemotherapy compared to radiochemotherapy. 138There is, however, no consensus regarding the utility of ^18^FDG-PET in predicting histological grading and survival of brain tumors. Differentiation between inflammatory tissue and malignancies is sometimes difficult due to the high degree of physiologic glucose metabolism in normal brain tissue. This makes the interpretation of increased ^18^FDG accumulation in both processes difficult. For example, when a hypermetabolic lesion is at the cortical or subcortical gray matter, tumor ^18^FDG uptake and normal ^18^FDG uptake are hard to differentiate. Because brain tumors are histologically heterogeneous, CT- or MRI-guided stereotactic brain biopsy does not always yield a valid diagnosis or grading. The correct diagnosis of a relapse is crucial for optimal further treatment. For example, ^18^FDG may help to distinguish between recurrences and radiation necrosis in cases of glioblastoma multiforme (GBM), and detection of early relapse can help to increase the benefit of interventions such as stereotactic irradiation or gamma knife treatment. Therefore, although the prognosis of GBM tumors remains poor, the use of ^18^FDG-PET may still have benefits in terms of patient survival time.

### 2.3 Results

Six studies26-30,129 provided evidence on the use of ^18^FDG-PET. We did not find studies that reported on the use of ^18^FDG-PET/CT for brain cancer. Five studies26-30 evaluated the diagnostic accuracy of ^18^FDG-PET for brain cancer. None of the studies reported on the diagnostic thinking impact of ^18^FDG-PET. One study129 evaluated the effects of ^18^FDG-PET as part of a management strategy on patient-centered outcomes. No economic evaluations on the use of ^18^FDG-PET or ^18^FDG-PET/CT for brain cancer were identified. Characteristics of the populations, conditions of ^18^FDG-PET administration, interpretation of results and methodological quality of the studies are summarized in Appendices D to J.

#### 2.3.1 Diagnostic accuracy of ^18^FDG-PET in brain cancer

##### Characteristics of the studies

Five studies (three prospective, 26-28 two retrospective29,30) evaluated the diagnostic accuracy of ^18^FDG-PET on brain cancer. ^18^FDG-PET was used for initial staging in three studies, 27,28,30 for assessment of recurrences in one study, 29 and for establishing both primary diagnosis and recurrences in the remaining study. 26 The studies contained a total of 217 patients with sample sizes ranging from 17 to 81 participants. Participant ages ranged from 20 to 76 years. Four studies reported the distribution by stage of cancer: CS I = 64 percent, CS II = 36 percent; 30 CS II = 22 percent, CS III = 16 percent, CS IV = 42 percent; 26 CS II = 27 percent, CS III = 42 percent, CS IV = 31 percent; 28 and CS I = 7 percent, CS II = 20 percent, CS III = 20 percent, CS IV = 47 percent. 27 ^18^FDG-PET was compared to a reference standard that varied across the studies. Three studies established the final diagnosis of all patients using histology/biopsy. 27,28,30 In one study the reference standard was either histology/biopsy or clinical followup. 26 One study used MRI and MET-PET (carbon-11 methionine and positron emission tomography) as reference standards in all patients. 29 One study reported the mean time between last treatment and ^18^FDG-PET as 4 months for chemotherapy, 12 months for radiotherapy and 13 months for surgery. 29 Two studies used a fixed dose of 370 MBq of ^18^FDG. 28,30 One study used a weight-based dose (2.4 MBq/kg), 26 while another study reported a dose range of 200-300 MBq. 29 The time between injection and PET scan was 30 minutes, 29 45 minutes, 28 and 60 minutes. 26,30 Patients fasted for four, 28,29 six, 27 or twelve30 hours. Two studies29,30 measured glucose levels before administration of ^18^FDG-PET; the maximum glucose level that was allowed was “normal levels” 29 and 5.6 mmol/L. 30 Methods of interpretation of the images were qualitative in two studies27,30 and both qualitative and quantitative in three. 26,28,29 Scans were interpreted qualitatively using visual analysis. 26-29 Two studies28,29 reported using SUV but the criteria for abnormality were not reported.

##### Comparisons

Comparisons for which data were considered for a meta-analysis on the accuracy of ^18^FDG-PET in detecting the stage of brain cancer are summarized in Table 9. Individual study data are summarized in Appendix D.

Table 9 Summary of comparisons considered for meta-analyses of the accuracy of ^18^FDG-PET for brain cancer

Indication | Studies | Design | Type of PET | Reference standard | Meta-analysis
Primary diagnosis and recurrences | Chen 2006^26^ | P | FDG-PET | Histology/biopsy or clinical followup | No
Recurrences | Potzi 2007^29^ | R | FDG-PET | MRI, MET-PET | No
Staging | Cher 2006^27^ | P | FDG-PET | Histology/biopsy | 1. FDG-PET v. histology/biopsy (P studies) 27,28
Staging | Liu 2006^28^ | P | FDG-PET | Histology/biopsy | 1. FDG-PET v. histology/biopsy (P studies) 27,28
Staging | Stockhammer 2007^30^ | R | FDG-PET | Histology/biopsy | 1. FDG-PET v. histology/biopsy (P studies) 27,28

FDG = fluorodeoxyglucose F18; MET = carbon-11 methionine; MRI = magnetic resonance imaging; P = prospective; PET = positron emission tomography; R = retrospective

###### 1 ^18^FDG-PET for the staging of brain cancer

Reference standard: histology/biopsy; prospective studies. Two prospective studies27,28 totaling 42 participants provided data for a meta-analysis of the accuracy of ^18^FDG-PET compared to histology for the staging of brain cancer. Individual 2x2 table results are presented in Figure 6. The sensitivity value in both of the individual studies was 63 percent. 27,28 Specificity data was provided by one study only28 (100 percent). We could not calculate a pooled estimate of the positive and negative LRs for the accuracy of the staging of brain cancer because the study by Cher27 provided sensitivity data only.

Figure 6 Results from 2x2 tables of individual prospective studies of ^18^FDG-PET v. histology for the staging of brain cancer

Figure 6 describes the results derived from the 2x2 tables of individual prospective studies of 18FDG-PET versus histology for the staging of brain cancer. The figure is described in Chapter 2 (page 36) as follows: "Two prospective studies (Cher and Liu) totaling 42 participants provided data for a metaanalysis of the accuracy of 18FDG-PET compared to histology for the staging of brain cancer. Sensitivity value in individual studies was 63% (Cher and Liu). Data to calculate specificity were provided by one study (Liu) and the value was 100%."

#### 2.3.2 ^18^FDG-PET as part of a management strategy in brain cancer

One study assessed the impact of ^18^FDG-PET as part of a management strategy of brain cancer at various stages of treatment. Padma et al. 129 conducted a retrospective study that examined the value of ^18^FDG-PET results for predicting the survival of patients with brain cancer. The study included 331 patients with a mean age of 47 years (59 percent males), histologically-proven brain tumors according to WHO criteria, and should have been followed up until death or at least one year after ^18^FDG-PET.

Prognostic value was assessed with respect to the ability of ^18^FDG-PET to predict the grade of glioma and patient survival. Patients were followed up for an average of 3.6 years after ^18^FDG-PET. One hundred and thirty-seven (41 percent) of the patients underwent ^18^FDG-PET prior to histological diagnosis and any therapeutic intervention, while 194 patients underwent ^18^FDG-PET between 2 months and 10 years following the histological diagnosis.

The influence of ^18^FDG-PET in predicting survival was found to be significant. Overall, the median survival of patients with high uptake scores on ^18^FDG-PET was 11 months v. 28 months in patients with low uptake scores. High ^18^FDG-PET uptake was strongly associated with poor survival; while cases with low uptake had increased likelihood of long term survival (4-5 years). The authors concluded that ^18^FDG-PET may help in the stratification of patients entered in protocols that evaluate therapeutic strategies in brain tumors. Additionally, the authors discussed the utility of ^18^FDG-PET v. grading by histology for predicting the survival of patients in whom the ^18^FDG-PET was done prior to surgery and any mode of therapeutic intervention.

Overall, the study was graded as level D of evidence (multiple flaws in methods). A detailed description of the methodological quality of this study is presented in Appendix H. The issues with the quality in the study included the lack of a comparator group who did not receive the ^18^FDG-PET as a component of their disease monitoring. The selection criteria were only partially described, raising the possibility of selection bias. While the study had a large population, there is only partial description of the population characteristics. The method of ^18^FDG-PET testing was not described sufficiently enough to permit reproducibility. Two different types of scans were used over the study period, and it is unknown how this may affect the detection of low or high ^18^FDG uptake and therefore, affect outcome assessment. Additionally, while this study was relevant to management strategy, a matched design was not employed.

Table 10 provides a summary of the main findings and the types of bias that affected the evidence on ^18^FDG-PET as part of a management strategy in brain cancer

Table 10 Main findings and types of bias that affected the evidence on ^18^FDG-PET as part of a management strategy in brain cancer

Study | Patient Centered Outcomes | | | Types of bias
Padma 2003^129^ Study type: Retrospective | FDG-PET used for: Predicting survival High FDG-uptake (n = 166) Low FDG-PET uptake (n = 165) | | | Selection bias (unclear) Disease progression bias (unclear) Review bias (RS unclear)
Padma 2003^129^ Study type: Retrospective | Survival | High uptake | Low Uptake | Selection bias (unclear) Disease progression bias (unclear) Review bias (RS unclear)
Padma 2003^129^ Study type: Retrospective | | | | Selection bias (unclear) Disease progression bias (unclear) Review bias (RS unclear)
Padma 2003^129^ Study type: Retrospective | < 1 y | 117/165 | 10/166 | Selection bias (unclear) Disease progression bias (unclear) Review bias (RS unclear)
Padma 2003^129^ Study type: Retrospective | | | | Selection bias (unclear) Disease progression bias (unclear) Review bias (RS unclear)
Padma 2003^129^ Study type: Retrospective | > 1 y | 48/165 | 156/166 | Selection bias (unclear) Disease progression bias (unclear) Review bias (RS unclear)
Padma 2003^129^ Study type: Retrospective | | | | Selection bias (unclear) Disease progression bias (unclear) Review bias (RS unclear)
Padma 2003^129^ Study type: Retrospective | > 2 y | 0/165 | 104/166 | Selection bias (unclear) Disease progression bias (unclear) Review bias (RS unclear)
Padma 2003^129^ Study type: Retrospective | | | | Selection bias (unclear) Disease progression bias (unclear) Review bias (RS unclear)
Padma 2003^129^ Study type: Retrospective | > 3 y | 0/165 | 65/166 | Selection bias (unclear) Disease progression bias (unclear) Review bias (RS unclear)
Padma 2003^129^ Study type: Retrospective | | | | Selection bias (unclear) Disease progression bias (unclear) Review bias (RS unclear)
Padma 2003^129^ Study type: Retrospective | 4 and 5 y | 0/165 | 49 and 26/166 | Selection bias (unclear) Disease progression bias (unclear) Review bias (RS unclear)

FDG = Fluorodeoxyglucose F18; PET = positron emission tomography; RS = reference standard; yr = years

## 3 Cervical Cancer

### 3.1 Background

In the United States in 2008, 11,070 women are expected to be diagnosed with new cases of cervical cancer and approximately 3,870 will die from the disease. 133 Incidence of cervical cancer varies greatly across subpopulations within the country. 139 Between 2000 and 2004 incidence rates of cervical cancer for Caucasian-American women were 8.5/100,000. For African-American women the numbers increase to 11.4/100,000 and the highest rate occurs in Hispanic-American women at 13.8/100,000. 133 Cervical cancer appears earlier in life than other malignancies. The median age at diagnosis is 48 years and the median age of death is 57 years. On average, cervical cancer accounts for 26.3 years of life lost in women diagnosed with this condition in the United States. 133

Sexual intercourse at an early age, multiple male sexual partners who also have multiple partners and smoking are considered risks factors associated with the disease. 140 The vast majority of cervical cancer cases (99.7 percent) are associated with human papilloma virus (HPV). 141 There are many different types of HPV. High risk viral subtypes of HPV raise the risk of developing high-grade cervical dysplasia and cancer. Immunosuppression due to renal-allograft transplantation or Hodgkin’s disease is also linked to cervical cancer. Precursors to cervical cancer known as cervical intraepithelial neoplasia (CIN) can occur in women less than 40 years of age. 140 HPV vaccines have helped to decrease rates of CIN significantly. Screening for cervical cancer using the Pap smear to assess for abnormal cervical cytology is commonplace in the United States. The Pap smear facilitates detection of precursor lesions, prior to the progression of disease to a more invasive cancer. Abnormal Pap findings require further evaluation with colposcopy and directed biopsies. 141

If diagnosed in the early stages of disease, a high cure rate can be achieved. However, cervical cancer is often asymptomatic140 and when left untreated, cervical cancer grows and frequently will metastasize into regional lymph nodes. 142 A patient may report vaginal discharge or postcoital vaginal bleeding. In cases of advanced disease lower extremity edema, deep vein thrombosis or ureteral obstruction may occur. 140 Two thirds of all cervical cancers are composed of squamous cell carcinoma, while much of the remaining 25 percent are adenocarcinoma. Tumors are staged using the International Federation of Gynaecology (FIGO) system, which takes tumor grade, depth, width and extent of invasion into consideration (Table 11). 143

Table 11 FIGO staging of cervical cancer

Stage | Description
Stage 0 | Carcinoma in situ
Stage Ia1 | Invasive carcinoma, confined to cervix, lesion ≤3 mm deep, ≤ 7 mm wide
Stage Ia2 | Invasive carcinoma, confined to cervix, lesion >3 mm and ≤ 5 mm deep, ≤ 7 mm wide
Stage Ib1 | Invasive carcinoma, confined to cervix, lesion ≤ 4 cm
Stage Ib2 | Invasive carcinoma, confined to cervix, lesion > 4 cm
Stage IIa | Tumor extended beyond cervix to vagina (but not lower 1/3)
Stage IIb | Tumor extended beyond cervix, parametrial invasion (but not to pelvic side wall or lower 1/3 of vagina)
Stage IIIa | Tumor extended to lower 1/3 of vagina (but not to pelvic side wall)
Stage IIIb | Tumor extended to pelvic side wall, interferes with kidney function
Stage IVa | Tumor extended into bladder or rectum
Stage IVb | Distant metastasis

Taken from Petignat et al. 143

Limitations to current screening and imaging modalities exist. Pap tests are commonly used to cytologically evaluate the cervix, but are subject to errors occurring during sample collection or evaluation. An alternative to conventional Pap testing is liquid-based cytology. Findings do not consistently demonstrate if liquid-based cytology is more effective than conventional Pap testing. 139 Regardless, screening is a useful tool and has dramatically reduced the incidence and mortality of cervical cancer.

Testing may also be conducted to detect HPV DNA. The United States and some European countries screen for specific biomarkers, which improves efficiency and maximizes sensitivity. It is an adjunctive test with cytology for women 20 years of age or older. Although screening for biomarkers is more sensitive and has high negative predictive values, it suffers from lower specificity than Pap tests as HPV infections are common in sexually active women. 139

When local disease is diagnosed, screening with CT or MRI is helpful for defining lymph node status and determining the extent of disease. Identifying involved nodes can be difficult as their identification relies on size and morphological criteria. Surgery provides another method for staging. Pelvic lymphadenectomy and para-aortic lymphadenectomy are two techniques frequently used. Many studies demonstrate excellent patient results after surgical staging. Imaging techniques such as CT, MRI and PET, in addition to surgical staging may be more effective in identifying the true extent of disease than clinical testing. However, these techniques have yet to be incorporated into the FIGO staging system. 143

^18^FDG-PET could have some advantages over CT in the imaging of cervical cancer. Lesion location can be identified with CT, but ^18^FDG-PET may be capable of detecting nodal involvement when CT is not. ^18^FDG-PET may also be useful in diagnosing recurrent and metastatic disease. 144

Cure can be achieved in 80 to 90 percent of patients with stage I and II disease when treated with surgery or chemoradiotherapy. 143 Surgery is usually performed first followed by chemotherapy or radiotherapy, which helps decrease the risk of reoccurrence. 140 Conisation is performed in woman with stage I disease if fertility is to be preserved; otherwise, simple hysterectomy is performed. Radical hysterectomy is performed for higher grade tumors; radical trachelctomy may provide a surgical option for younger women who wish to preserve fertility. 143 Relapse occurs frequently in patients with stages IIb, III and IV even after treatment with surgery and radiotherapy. 140 Recurrences usually occur within two years after the completion of primary treatment. 143 Approximately 30 percent of women with invasive cancer die from recurrence. 140 The goal for treatment of patients with stage IVb cancer is palliative. How treatment affects quality of life and toxicity influences choice of treatment. 143

### 3.2 Importance of Key Questions in the Clinical Management of Cervical Cancer

Cervical cancer spreads directly through the lymphatic system, with pelvic node metastasis preceding aortic node metastasis in the majority of the cases. Sensitive and specific imaging modalities that identify occult lymph node metastasis may help avoid morbid surgical procedures and facilitate treatment planning with novel modalities. Earlier detection of recurrent cervical cancer has the potential to improve survival, since some patients may be salvaged using radiotherapy or radical surgery. Local recurrences may be difficult to detect by anatomical examination because the soft tissue structures are thickened following radiation or surgery. Anatomical imaging techniques such as CT and MRI can be fairly inaccurate in detecting retroperitoneal nodal metastasis and therefore, it is important to explore whether functional imaging methods such as ^18^FDG-PET can help to improve the accuracy of pretreatment staging and have a positive impact on patient survival. It is important to determine whether the use of ^18^FDG-PET in patients with cervical cancer can improve patient-centered outcomes by altering the primary management strategies. As the available treatments for cervical cancer recurrence improve, such as radical resection in combination with intraoperative high-dose-rate brachytherapy, the improvement of imaging modalities to identify recurrences early becomes more important.

### 3.3 Results

Thirty-three studies31-63 provided evidence on the use of ^18^FDG-PET or ^18^FDG-PET/CT for cervical cancer. All of the studies evaluated the diagnostic accuracy of ^18^FDG-PET or ^18^FDG-PET/CT for cervical cancer. Six studies reported on the diagnostic thinking impact of ^18^FDG-PET33,43,44,61 and ^18^FDG-PET/CT, 32,38 and two studies33,43 evaluated the impact of ^18^FDG-PET as part of a management strategy on patient-centered outcomes. No economic evaluations on the use of ^18^FDG-PET and ^18^FDG-PET/CT for cervical cancer were identified. Characteristics of the populations, conditions of ^18^FDG-PET and ^18^FDG-PET/CT administration, interpretation of results and methodological quality of the studies are summarized in Appendices D to J.

#### 3.3.1 Diagnostic accuracy of ^18^FDG-PET and ^18^FDG-PET/CT in cervical cancer

##### Characteristics of the studies

Thirty-three studies (21 prospective, 31-33,35-37,40,42-47,49,51-53,60-63 12 retrospective34,38,39,41,48,50,54-59) evaluated the diagnostic accuracy of ^18^FDG-PET 33-35,37,39-45,47-51,54-62 and ^18^FDG-PET/CT 31,32,36,38,46,52,53,59,63 on cervical cancer. Ten studies37,42,45,47-49,54,55,59,62 used ^18^FDG-PET for initial staging, one for primary diagnosis and recurrence, ^35^11 for recurrence, 33,34,39,41,44,50,51,56,57,60,61 one for restaging, 43 one for staging and recurrence, 40 and one for staging and restaging. 58 Six studies used ^18^FDG-PET/CT for initial staging, 31,36,46,53,59,63 two for recurrence38,52 and one for staging and restaging purposes. 32 The studies contained a total of 2,767 patients with sample sizes ranging from 14 to 517 participants. Participant ages ranged from 20 to 87 years. Twenty-seven studies reported the distribution by stage of cancer32-39,41-44,46,48-53,55-57,59-63 and included variously all stages from IA1 to stage IV. ^18^FDG-PET was compared to histology/biopsy in all studies, but in 19 studies the reference standard also included clinical followup, 31-35,38-40,43,44,46,50,52,56-58,60-62 and in one47 imaging followup was also used. Twelve studies32-34,38,44,47,51-53,56,57,63 reported the mean time between last treatment and ^18^FDG-PET, which ranged from 7 days53 to 42 months. 47 Seventeen studies reported using a fixed dose of ^18^FDG (322MBq, 48 370MBq, 33-35,37,43-45,47,52,53,57,61,62 400MBq, 46 550MBq55,56); four studies used a weight-based dose (0.14mCi/kg, 41 0.22mCi/kg, 38 5MBq/kg, 48 5.2MBq/kg58). The time between injection and PET scan ranged from 30 minutes34 to 3 hours. 47 Patients fasted anywhere from 4 hours31,32,34,38,40,45,51,55,56,63 to overnight. 145 Seven studies31,32,35,47,52,53,57 measured glucose levels before administration of ^18^FDG-PET; the maximum glucose level permitted was 200 mg/dL. 31,52 Methods of interpretation of the images were quantitative in one study, 51 qualitative in 16 studies32-34,37,38,41,44,45,47,50,52,53,56-58,61 and both qualitative and quantitative in 8 studies. 35,36,39,43,48,49,60,62 Scans were interpreted qualitatively using visual analysis in 26 studies. 32-39,41,43-45,47-53,56-62 Four studies36,39,47,49 reported using both visual analysis and SUV and one51 used SUV only.

##### Comparisons

Comparisons for which data were considered for meta-analysis are summarized in Table 12. Pooled data were obtained to evaluate the accuracy of ^18^FDG-PET in cervical cancer for staging and for detection of recurrences. Pooled data were also obtained to evaluate the accuracy of ^18^FDG-PET/CT for staging of cervical cancer. Individual study data are summarized in Appendix D.

Table 12 Summary of comparisons considered for meta-analyses of the accuracy of ^18^FDG-PET and ^18^FDG-PET/CT for cervical cancer

Indication | Studies | Design | Type of PET | Reference standard | Meta-analysis
Primary diagnosis and recurrences | Chang 2005^35^ | P | FDG-PET | Histology/biopsy or clinical followup | No
Staging and recurrences | Grisaru 2004^40^ | P | FDG-PET | Histology/biopsy | No
Staging and restaging | Bjurberg 2007^32^ | P | FDG-PET/CT | Histology/biopsy or clinical followup | No
Staging and restaging | Wong 2004^58^ | R | FDG-PET | Histology/biopsy or clinical followup | No
Recurrences | Chang 2004^33^ | P | FDG-PET | Histology/biopsy or clinical followup (local v. distant) | 1. FDG-PET v. histology/biopsy or clinical followup (P studies) 44,60,61 2. FDG-PET v. histology/biopsy or clinical followup (R studies) 39,50,56
Recurrences | Chang 2004^34^ | R | FDG-PET | Histology/biopsy or clinical followup (lesion-based) | 1. FDG-PET v. histology/biopsy or clinical followup (P studies) 44,60,61 2. FDG-PET v. histology/biopsy or clinical followup (R studies) 39,50,56
Recurrences | Chung 2007^38^ | R | FDG-PET/CT | Histology/biopsy or clinical followup | 1. FDG-PET v. histology/biopsy or clinical followup (P studies) 44,60,61 2. FDG-PET v. histology/biopsy or clinical followup (R studies) 39,50,56
Recurrences | Chung 2006^39^ | R | FDG-PET | Histology/biopsy or clinical followup | 1. FDG-PET v. histology/biopsy or clinical followup (P studies) 44,60,61 2. FDG-PET v. histology/biopsy or clinical followup (R studies) 39,50,56
Recurrences | Havrilesky 2003^41^ | R | FDG-PET | Histology/biopsy (lesion-based) | 1. FDG-PET v. histology/biopsy or clinical followup (P studies) 44,60,61 2. FDG-PET v. histology/biopsy or clinical followup (R studies) 39,50,56
Recurrences | Lin 2006^44^ | P | FDG-PET | Histology/biopsy or clinical followup | 1. FDG-PET v. histology/biopsy or clinical followup (P studies) 44,60,61 2. FDG-PET v. histology/biopsy or clinical followup (R studies) 39,50,56
Recurrences | Ryu 2003^50^ | R | FDG-PET | Histology/biopsy or clinical followup | 1. FDG-PET v. histology/biopsy or clinical followup (P studies) 44,60,61 2. FDG-PET v. histology/biopsy or clinical followup (R studies) 39,50,56
Recurrences | Sakurai 2006^51^ | P | FDG-PET/CT | Histology/biopsy (lesion-based) | 1. FDG-PET v. histology/biopsy or clinical followup (P studies) 44,60,61 2. FDG-PET v. histology/biopsy or clinical followup (R studies) 39,50,56
Recurrences | Sironi 2007^52^ | P | FDG-PET | Histology/biopsy or clinical followup | 1. FDG-PET v. histology/biopsy or clinical followup (P studies) 44,60,61 2. FDG-PET v. histology/biopsy or clinical followup (R studies) 39,50,56
Recurrences | Unger 2004^56^ | R | FDG-PET | Histology/biopsy or clinical followup | 1. FDG-PET v. histology/biopsy or clinical followup (P studies) 44,60,61 2. FDG-PET v. histology/biopsy or clinical followup (R studies) 39,50,56
Recurrences | Van Der Veldt 2006^57^ | R | FDG-PET | Histology/biopsy (lesion-based) | 1. FDG-PET v. histology/biopsy or clinical followup (P studies) 44,60,61 2. FDG-PET v. histology/biopsy or clinical followup (R studies) 39,50,56
Recurrences | Yen 2006^60^ | P | FDG-PET | Histology/biopsy or clinical followup | 1. FDG-PET v. histology/biopsy or clinical followup (P studies) 44,60,61 2. FDG-PET v. histology/biopsy or clinical followup (R studies) 39,50,56
Recurrences | Yen 2004^61^ | P | FDG-PET | Histology/biopsy or clinical followup | 1. FDG-PET v. histology/biopsy or clinical followup (P studies) 44,60,61 2. FDG-PET v. histology/biopsy or clinical followup (R studies) 39,50,56
Restaging | Lai 2004^43^ | P | FDG-PET | Histology/biopsy or clinical followup | No
Staging | Amit 2006^31^ | P | FDG-PET/CT | Histology/biopsy or clinical followup | 1. FDG-PET v. any reference standard (P studies) 37,42,45,47,49 2. FDG-PET v. histology (P studies) 37,42,45,49 3. FDG-PET v. histology (R studies) 48,54,55 4. FDG-PET/CT v. any reference standard (P studies) 31,46,63 5. FDG-PET/CT v. histology/biopsy or clinical followup (P studies) 31,46
Staging | Choi 2006^36^ | P | FDG-PET/CT | Histology/biopsy (lesion-based)
Staging | Chou 2006^37^ | P | FDG-PET | Histology/biopsy
Staging | Hope 2006^42^ | P | FDG-PET | Histology/biopsy
Staging | Lin 2003^45^ | P | FDG-PET | Histology/biopsy
Staging | Loft 2007^46^ | P | FDG-PET/CT | Histology/biopsy or clinical followup
Staging | Ma 2003^47^ | P | FDG-PET | Histology/biopsy and imaging followup
Staging | Park 2005^48^ | R | FDG-PET | Histology/biopsy
Staging | Roh 2005^49^ | P | FDG-PET | Histology/biopsy
Staging | Sironi 2006^53^ | P | FDG-PET/CT | Histology/biopsy (node based)
Staging | Tran 2003^54^ | R | FDG-PET | Histology/biopsy
Staging | Unger 2005^55^ | R | FDG-PET | Histology/biopsy
Staging | Wright 2005^59^ | R | FDG-PET and FDG-PET/CT | Histology/biopsy
Staging | Yen 2003^62^ | P | FDG-PET | Histology/biopsy or clinical followup (lesion-based)
Staging | Yildirim 2008^63^ | P | FDG-PET/CT | Histology/biopsy

CT = computed tomography; FDG = fluorodeoxyglucose F18; P = prospective; PET = positron emission tomography; R = retrospective

###### 1 ^18^FDG-PET for recurrences of cervical cancer

Reference standard: histology/biopsy or clinical followup; prospective studies. Three prospective studies44,60,61 totaling 231 participants provided data for a meta-analysis of the accuracy of ^18^FDG-PET compared to histology/biopsy or clinical followup for detecting recurrences of cervical cancer. Recurrences were identified by site including peritoneum, bone, liver/spleen, lung, mediastinal lymph node (MLN), supraclavicular lymph node (SLN), para-aortic lymph node (PALN), pelvic lymph node (PLN), and inguinal lymph node (ILN). Individual 2x2 table results are presented in Figure 7. Sensitivity values in individual studies ranged from 50 percent for bone and PLN sites44 to 100 percent for liver/spleen, 44,60 MLN44,60,61 and ILN44,60 sites. Specificity ranged from 88 percent for MLN44 to 100 percent for bone, 60 liver/spleen, 44 lung, 44,60 PALN, 60 PLN44 and ILN. 44,61

Figure 7 Results from 2x2 tables of individual prospective studies of ^18^FDG-PET v. histology/biopsy or clinical followup to detect recurrences of cervical cancer

Figure 7 is a forest plot-type diagram that reports the sensitivity and specificity of 18FDG-PET versus histology/biopsy or clinical followup to detect recurrences of cervical cancer. It is discussed in Chapter 2 (page 44). Three prospective studies (Lin 2006, Yen 2004, Yen 2006) totaling 231 participants provided data for a meta-analysis. Recurrences were analyzed by site including peritoneum, bone, liver/spleen, lung, mediastinal lymph node (MLN), supraclavicular lymph node (SLN), para-aortic lymph node (PALN), pelvic lymph node (PLN), and inguinal lymph node (ILN). Sensitivity values in individual studies ranged from 50% (Lin 2006) for bone and PLN sites to 100% for liver/spleen, (Lin 2006, Yen 2004) MLN (Lin 2006, Yen 2004, Yen 2006) and ILN (Yen 2004, Yen 2006) sites. Specificity ranged from 88% for MLN (Lin 2006) to 100% for liver/spleen,(Lin 2006) lung, (Lin 2006, Yen 2004) PALN,(Yen 2004) PLN (Lin 2006) and ILN. (Lin 2006, Yen 2004)"

Figures 8 and 9 present the positive and negative LRs of ^18^FDG-PET v. histology/biopsy or clinical followup to detect recurrences of cervical cancer. We found that all the positive LRs by site of recurrence were statistically significant ranging from 15.24 (95% CI = 5.63, 41.27) for MLN to 45.89 (95% CI = 14.09, 149.49) for liver/spleen. Overall, the positive LRs across the studies were homogeneous except for MLN, where moderate heterogeneity was found across the studies (p = 0.12; I^2^ = 53 percent). All the negative LRs by site of recurrence were statistically significant except for the identification of bone recurrences. Negative LRs ranged from 0.09 (95% CI = 0.02, 0.40) for MLN to 0.37 (95% CI = 0.22, 0.60) for peritoneum. The negative LRs across the studies were homogeneous except for the identification of recurrences in bone (p = 0.07; I^2^ = 70 percent) and PLN (p = 0.03; I^2^ = 71 percent).

Figure 8 Meta-analysis of the positive likelihood ratio of ^18^FDG-PET v. histology/biopsy or clinical followup to detect recurrences of cervical cancer (prospective studies; data presented by site)

Figure 8 is a meta-graph depicting the positive likelihood ratio of 18FDG-PET versus histology/biopsy or clinical followup to detect recurrences of cervical cancer. It is discussed in Chapter 2 (page 46). Recurrences were analyzed by site including peritoneum, bone, liver/spleen, lung, mediastinal lymph node (MLN), supraclavicular lymph node (SLN), para-aortic lymph node (PALN), pelvic lymph node (PLN), and inguinal lymph node (ILN). We found that all the positive LR by site of recurrence were statistically significant ranging from 15.24 (95% CI = 5.63, 41.27) for MLN to 45.89 (95% CI = 14.09, 149.49 for liver/spleen. Overall, the positive LRs across the studies were homogeneous except for MLN, where moderate heterogeneity was found across the studies (p = 0.12; I2 = 53 percent).

Figure 9 Meta-analysis of the negative likelihood ratio of ^18^FDG-PET v. histology/biopsy or clinical followup to detect recurrences of cervical cancer (prospective studies; data presented by site)

Figure 9 is a meta-graph depicting the negative likelihood ratio of 18FDG-PET versus histology/biopsy or clinical followup to detect recurrences of cervical cancer. It is discussed in Chapter 2 (page 46). Recurrences were analyzed by site including peritoneum, bone, liver/spleen, lung, mediastinal lymph node (MLN), supraclavicular lymph node (SLN), para-aortic lymph node (PALN), pelvic lymph node (PLN), and inguinal lymph node (ILN). All the negative LRs by site of recurrence were statistically significant except for the identification of bone recurrences. Negative LR ranged from 0.09 (95% CI = 0.02, 0.40) for MLN to 0.37 95% CI = 0.22, 0.60) for peritoneum. The negative LR across the studies were homogeneous except for the identification of recurrences in bone (p = 0.07; I2 = 70 percent) and PLN (p = 0.03; I2 = 71 percent).

Figure 10 shows the estimates of sensitivity and 1-specificity plotted in ROC space for ^18^FDG-PET v. histology/biopsy or clinical followup to detect recurrences of cervical per site of lesion cancer based on prospective studies.

Figure 10 Summary ROC plot of ^18^FDG-PET v. histology/biopsy or clinical followup to detect recurrences of cervical cancer (prospective studies; data presented by site)

Figure 10 is a summary ROC plot that shows the estimates of sensitivity and 1-specificity plotted in ROC space for 18FDG-PET versus histology/biopsy or clinical followup to detect recurrences of cervical cancer (prospective studies, data presented by site). It is discussed in Chapter 2 (page 49). The curve appears near the top left-hand corner.

Reference standard: histology/biopsy or clinical followup; retrospective studies. Separate meta-analyses were conducted for retrospective studies. Three retrospective studies39,50,56 totaling 396 participants provided data for a meta-analysis of the accuracy of ^18^FDG-PET compared to histology/biopsy or clinical followup for detecting recurrences of cervical cancer. Individual 2x2 table results are presented in Figure 11. Sensitivity values in individual studies ranged from 80 percent56 to 96 percent. 39 Specificity ranged from 76 percent50 to 100 percent. 56

Figure 11 Results from 2x2 tables of individual retrospective studies of ^18^FDG-PET v. histology/biopsy or clinical followup for detecting recurrences of cervical cancer

Based on the analysis of retrospective studies, we found that ^18^FDG-PET had a pooled positive LR of 5.33 (95% CI = 2.36, 12.05) and a pooled negative LR of 0.11 (95% CI = 0.04, 0.28) to accurately detect recurrences of cervical cancer (Figures 12 and 13). The positive and negative LRs were consistently positive and statistically significant and therefore, ^18^FDG-PET seems to be helpful to identify recurrences of the disease. However, the magnitude of both the positive (p = 0.03; I^2^ = 70 percent) and the negative (p = 0.12; I^2^ = 53 percent) LRs were heterogeneous across the studies, therefore the magnitude of the effect is less certain.

Figure 12 Meta-analysis of the positive likelihood ratio of ^18^FDG-PET v. histology/biopsy or clinical followup for detecting recurrences of cervical cancer (retrospective studies)

Figure 12 is a meta-graph depicting the positive likelihood ratio of 18FDG-PET versus histology/biopsy or clinical followup for detecting recurrences of cervical cancer based on retrospective studies. It is discussed in Chapter 2 (page 50). 18FDG-PET had a pooled positive likelihood ratio of 5.33 (95% CI 2.36, 12.05) to accurately detect recurrences of cervical cancer. The positive likelihood ratio was statistically significant and therefore, 18FDG-PET/CT seems to be helpful to identify recurrences of the disease. However, the positive (p = 0.03; I2 = 70 percent) likelihood ratio was heterogeneous across the studies precluding firm conclusions based on these results.

Figure 13 Meta-analysis of the negative likelihood ratio of ^18^FDG-PET v. histology/biopsy or clinical followup for detecting recurrences of cervical cancer (retrospective studies)

Figure 13 is a meta-graph depicting the negative likelihood ratio of 18FDG-PET versus histology/biopsy or clinical followup for detecting recurrences of cervical cancer based on retrospective studies. It is discussed in Chapter 2 (page 50). 18FDG-PET had a pooled negative likelihood ration of 0.11 (95% CI = 0.04, 0.28) to accurately detect recurrences of cervical cancer. The negative likelihood ratio was statistically significant and therefore, 18FDG-PET/CT seems to be helpful to identify recurrences of the disease. However, the negative (p = 0.12; I2 = 53 percent) likelihood ration was heterogeneous across the studies precluding firm conclusions based on these results.

Figure 14 shows the estimates of sensitivity and 1-specificity plotted in ROC space for ^18^FDG-PET v. histology/biopsy or clinical followup for detecting recurrences of cervical cancer.

Figure 14 Summary ROC plot of ^18^FDG-PET v. any reference standard for detecting recurrences of cervical cancer (retrospective studies)

Figure 14 is a summary ROC plot that shows the estimates of sensitivity and 1-specificity plotted in ROC space for 18FDG-PET versus histology/biopsy or clinical followup for detecting recurrences of cervical cancer. It is discussed in Chapter 2 (page 51). The curve appears near the top left-hand corner.

###### 2 ^18^FDG-PET for the staging of cervical cancer

Reference standard: any; prospective studies. Five prospective studies37,42,45,47,49 totaling 325 participants provided data for a meta-analysis of the accuracy of ^18^FDG-PET compared to a variety of reference standards for the staging of cervical cancer. Individual 2x2 table results are presented in Figure 15. Sensitivity ranged from 10 percent37 to 86 percent. 45 Specificity ranged from 76 percent42 to 98 percent. 49

Figure 15 Results from 2x2 tables of individual prospective studies of ^18^FDG-PET v. any reference standard for the staging of cervical cancer

We found that ^18^FDG-PET had a pooled positive LR of 8.22 (95% CI = 2.59, 26.08) and a pooled negative LR of 0.38 (95% CI = 0.12, 1.20) to accurately identify the stage of cervical cancer (Figures 16 and 17). The pooled positive LR was statistically significant and therefore, ^18^FDG-PET seems to be helpful to detect the stage of the disease. The negative LR was not statistically significant and therefore, ^18^FDG-PET does not seem to be helpful in ruling out the presence of particular stages of the disease. There was high heterogeneity across the studies in the positive LR (p = 0.01; I^2^ = 69 percent) and negative LR (p < 0.000001; I^2^ = 95 percent).

Figure 16 Meta-analysis of the positive likelihood ratio of ^18^FDG-PET v. any reference standard for the staging of cervical cancer (prospective studies)

Figure 16 is a meta-graph depicting the positive likelihood ratio of 18FDG-PET compared to a variety of reference standards for the staging of cervical cancer. It is discussed in Chapter 2 (page 52). We found that18FDG-PET had a pooled positive likelihood ratio of 8.22 (95% CI 2.59, 26.08) to accurately identify the stage of cervical cancer. The pooled positive likelihood ratio was statistically significant and therefore, 18FDG-PET seems to be helpful to detect the stage of the disease. There was high heterogeneity (p = 0.01; I2 = 69 percent) across the studies.

Figure 17 Meta-analysis of the negative likelihood ratio of ^18^FDG-PET v. any reference standard for the staging of cervical cancer (prospective studies)

Figure 17 is a meta-graph depicting the negative likelihood ratio of 18FDG-PET compared to a variety of reference standards for the staging of cervical cancer. It is discussed in Chapter 2 (page 52). We found that18FDG-PET had a pooled negative likelihood ratio of 0.38 (95% CI = 0.12, 1.20) to accurately identify the stage of cervical cancer. The pooled negative likelihood ratio was not statistically significant and therefore 18FDG-PET does not seem to be helpful to ruling out the presence of particular stages of the disease. There was high heterogeneity (p=<0.000001; I2 = 95 percent) across the studies.

Figure 18 shows the estimates of sensitivity and 1-specificity plotted in ROC space for ^18^FDG-PET v. any reference standard for the staging of cervical cancer based on prospective studies.

Figure 18 Summary ROC plot of ^18^FDG-PET v. any reference standard for the staging of cervical cancer (prospective studies)

Figure 17 is a meta-graph depicting the negative likelihood ratio of 18FDG-PET compared to a variety of reference standards for the staging of cervical cancer. It is discussed in Chapter 2 (page 52). We found that18FDG-PET had a pooled negative likelihood ratio of 0.38 (95% CI = 0.12, 1.20) to accurately identify the stage of cervical cancer. The pooled negative likelihood ratio was not statistically significant and therefore 18FDG-PET does not seem to be helpful to ruling out the presence of particular stages of the disease. There was high heterogeneity (p=<0.000001; I2 = 95 percent) across the studies

Reference standard: histology/biopsy; prospective studies. Four prospective studies37,42,45,49 totaling 221 participants provided data for a subgroup analysis of the accuracy of ^18^FDG-PET when histology/biopsy or clinical followup were used as the reference standard for the staging of cervical cancer. Individual 2x2 table results are presented in Figure 19. Sensitivity ranged from 10 percent37 to 86 percent. 45 Specificity ranged from 76 percent42 to 98 percent. 49

Figure 19 Results from 2x2 tables of individual prospective studies of ^18^FDG-PET v. histology/biopsy or clinical followup for the staging of cervical cancer

We found that when only histology/biopsy were considered as the reference standard, ^18^FDG-PET had a pooled positive LR of 5.79 (95% CI = 1.88, 17.88) and a pooled negative LR of 0.47 (95% CI = 0.17, 1.32) to accurately identify the staging of cervical cancer (Figures 20 and 21). Both the positive and negative LRs were statistically significant and therefore, ^18^FDG-PET seems to help to classify the stage of the disease. However, both the positive (p = 0.08; I^2^ = 56 percent) and the negative (p < 0.000001; I^2^ = 92 percent) LRs were heterogeneous across the studies precluding firm conclusions based on these results.

Figure 20 Meta-analysis of the positive likelihood ratio of ^18^FDG-PET v. histology/biopsy or clinical followup for the staging of cervical cancer (prospective studies)

Figure 20 is a meta-graph depicting the positive likelihood ratio of 18FDG-PET versus histology/biopsy or clinical followup for the staging of cervical cancer based on prospective studies. It is discussed in Chapter 2 (page 54). When only histology/biopsy were considered as the reference standard, 18FDG-PET had a pooled positive likelihood ratio of 5.79 (95% CI 1.88, 17.88) to accurately identify the staging of cervical cancer. The positive likelihood ratio was statistically significant and therefore, 18FDG-PET seems to help classify the stage of the disease. However, the positive (p = 0.08; I2 = 56 percent) likelihood ratio was heterogeneous across the studies precluding firm conclusions based on these results.

Figure 21 Meta-analysis of the negative likelihood ratio of ^18^FDG-PET v. histology/biopsy or clinical followup for the staging of cervical cancer (prospective studies)

Figure 21 is a meta-graph depicting the negative likelihood ratio of 18FDG-PET versus histology/biopsy or clinical followup for the staging of cervical cancer based on prospective studies. It is discussed in Chapter 2 (page 54). When only histology/biopsy were considered as the reference standard, 18FDG-PET had a pooled negative likelihood ratio of 0.47 (95% CI = 0.17, 1.32) to accurately identify the staging of cervical cancer. The negative likelihood ratio was statistically significant and therefore, 18FDG-PET seems to help classify the stage of the disease. However, the negative likelihood ratio (p < 0.000001; I2 = 92 percent) was heterogeneous across the studies precluding firm conclusions based on these results.

Figure 22 shows the estimates of sensitivity and 1-specificity plotted in ROC space for ^18^FDG-PET v. histology/biopsy or clinical followup for the staging of cervical cancer.

Figure 22 Summary ROC plot of ^18^FDG-PET v. histology/biopsy or clinical followup for the staging of cervical cancer (prospective studies)

Figure 22 is a summary receiver operating characteristics plot of 18FDG-PET versus histology/biology or clinical followup for the staging of cervical cancer (prospective studies). The figure shows the paired estimates of sensitivity and 1-specificity for each of the four included studies. Specificity is recorded on the X-axis and sensitivity is recorded on the Y-axis. The curve appears in the top left hand corner (page 55).

Reference standard: histology/biopsy; retrospective studies. A separate meta-analysis was conducted for retrospective studies of ^18^FDG-PET compared to histology/biopsy for the staging of cervical cancer. Three retrospective studies48,54,55 totaling 236 participants provided data for a meta-analysis of the accuracy of ^18^FDG-PET compared to histology/biopsy for the staging of cervical cancer. Individual 2x2 table results are presented in Figure 23. Sensitivity values ranged from 29 percent55 to 100 percent. 54 Specificity was 100 percent across the three studies.

Figure 23 Results from 2x2 tables of individual retrospective studies of ^18^FDG-PET v. histology/biopsy or clinical followup for the staging of cervical cancer

Based on the analysis of the retrospective studies, we found that ^18^FDG-PET had a pooled positive LR of 32.90 (95% CI = 2.89, 375.25) and a pooled negative LR of 0.41 (95% CI = 0.11, 1.55) to accurately identify the stage of cervical cancer (Figures 24 and 25). The positive LR was statistically significant; however, the results were moderately heterogeneous across the studies (p = 0.11; I^2^ = 55 percent). The negative LR was not statistically significant and therefore, the test does not seem to be helpful in ruling out the presence of particular stages of the disease.

Figure 24 Meta-analysis of the positive likelihood ratio of ^18^FDG-PET v. histology/biopsy or clinical followup for the staging of cervical cancer (retrospective studies)

Figure 24 is a meta-graph of the positive likelihood ratio of 18FDG-PET versus histology/biopsy or clinical followup for the staging of cervical cancer (retrospective studies). Three studies contributed data from 236 participants. This figure is described in Chapter 3 (page 56). The pooled positive likelihood ratio to correctly stage disease was 32.90 (95% confidence interval 2.89, 375.25). This ratio was statistically significant; however, the results were moderately heterogeneous across the studies (p = 0.11, I2 = 55 percent).

Figure 25 Meta-analysis of the negative likelihood ratio of ^18^FDG-PET v. histology/biopsy or clinical followup for the staging of cervical cancer (retrospective studies)

Figure 25 is a meta-graph of the positive likelihood ratio of 18FDG-PET versus histology/biopsy or clinical followup for the staging of cervical cancer (retrospective studies). Three studies contributed data from 236 participants. This figure is described in Chapter 3 (page 56). The pooled negative likelihood was 0.41 (95% confidence interval 0.11, 1.55) to accurately identify the stage of cervical cancer. This ratio was not statistically significant.

Figure 26 shows the estimates of sensitivity and 1-specificity plotted in ROC space for ^18^FDG-PET v. histology/biopsy or clinical followup for the staging of cervical cancer based on retrospective studies.

Figure 26 Summary ROC plot of ^18^FDG-PET v. histology/biopsy or clinical followup for the staging of cervical cancer (retrospective studies)

Figure 26 is a summary receiver operating characteristics plot 18FDG-PET versus histology/biopsy or clinical followup for the staging of cervical cancer based on retrospective studies. The figure shows the paired estimates of sensitivity and 1-specificity for each of the three included studies. Specificity is recorded on the X-axis and sensitivity is recorded on the Y-axis. The curve appears in the top left hand corner (page 57).

###### 3 ^18^FDG-PET/CT for the staging of cervical cancer

Reference standard: any; prospective studies. Three prospective studies31,46,63 totaling 127 participants provided data for a meta-analysis of the accuracy of ^18^FDG-PET/CT compared to a variety of reference standards for the staging of cervical cancer. Individual 2x2 table results are presented in Figure 27. Sensitivity values ranged from 50 percent63 to 100 percent. 46 Specificity ranged from 83 percent63 to 94 percent. 31

Figure 27 Results from 2x2 tables of individual prospective studies of ^18^FDG-PET/CT v. any reference standard for the staging of cervical cancer

We found that ^18^FDG-PET/CT had a pooled positive LR of 6.89 (95% CI = 3.82, 12.42) and a pooled negative LR of 0.28 (95% CI = 0.06, 1.38) to accurately identify the stage of cervical cancer (Figures 28 and 29). The positive LR was statistically significant and the results were homogeneous across the studies and therefore, ^18^FDG-PET/CT seems to be helpful to identify the stage of the disease. The negative LR was not statistically significant and the results were quite heterogeneous across the studies (p = 0.004; I^2^ = 82 percent) and therefore, ^18^FDG-PET/CT does not seem to be helpful in ruling out particular stages of the disease.

Figure 28 Meta-analysis of the positive likelihood ratio of ^18^FDG-PET/CT v. any reference standard for the staging of cervical cancer (prospective studies)

Figure 28 is a meta-graph of the positive likelihood ratio of 18FDG-PET versus any reference standard for the staging of cervical cancer (prospective studies). Three studies contributed data from 127 participants. This figure is described in Chapter 3 (page 58). The pooled positive likelihood ratio was 6.89 (95% confidence interval 3.82, 12.42) to accurately identify the stage of cervical cancer. This ratio was statistically significant and the results were homogeneous across the studies.

Figure 29 Meta-analysis of the negative likelihood ratio of ^18^FDG-PET/CT v. any reference standard for the staging of cervical cancer (prospective studies)

Figure 29 is a meta-graph of the negative likelihood ratio of 18FDG-PET versus any reference standard for the staging of cervical cancer (prospective studies). Three studies contributed data from 127 participants. The figure is described in Chapter 3 (page 58). The pooled negative likelihood ratio was 0.28 (95% confidence interval 0.06, 1.38) to accurately identify the stage of cervical cancer. This ratio was not statistically significant, and the results were quite heterogeneous across the studies (p = 0.004, I2 = 82 percent).

Figure 30 shows the estimates of sensitivity and 1-specificity plotted in ROC space for ^18^FDG-PET/CT v. any reference standard for the staging of cervical cancer.

Figure 30 Summary ROC plot of ^18^FDG-PET/CT v. any reference standard for the staging of cervical cancer (prospective studies)

Figure 30 is a summary receiver operating characteristics plot of 18FDG-PET versus any reference standard for the staging of cervical cancer. The figure shows the paired estimates of sensitivity and 1-specificity for each of the three included studies. Specificity is recorded on the X-axis and sensitivity is recorded on the Y-axis. The curve appears in the upper left hand corner (page 59).

Reference standard: histology/biopsy or clinical followup; prospective studies. Two prospective studies31,46 totaling 111 participants provided data for a subgroup analysis of the accuracy of ^18^FDG-PET/CT compared to histology/biopsy or clinical followup for the staging of cervical cancer. Individual 2x2 table results are presented in Figure 31. Sensitivity values were 60 percent31 and 100 percent. 46 Specificity values were 88 percent46 and 94 percent. 31

Figure 31 Results from 2x2 tables of individual prospective studies of ^18^FDG-PET/CT v. histology/biopsy or clinical followup for the staging of cervical cancer

We found that when only histology/biopsy were considered as the reference standard, ^18^FDG-PET/CT had a pooled positive LR of 7.85 (95% CI = 4.16, 14.80) and a pooled negative LR of 0.12 (95% CI = 0.00, 10.08) to accurately identify the stage of cervical cancer (Figures 32 and 33). The positive LR was statistically significant and the results were homogeneous across the studies and therefore, ^18^FDG-PET/CT seems to be helpful to identify the stage of the disease. The negative LR was not statistically significant and the results were quite heterogeneous across the studies (p = 0.002; I^2^ = 90 percent) and therefore, ^18^FDG-PET/CT does not seem to be helpful to rule out particular stages of the disease.

Figure 32 Meta-analysis of the positive likelihood ratio of ^18^FDG-PET/CT v. histology/biopsy or clinical followup for the staging of cervical cancer (prospective studies)

Figure 32 is a meta-graph of the positive likelihood ratio of 18FDG-PET versus histology/biopsy or clinical followup for the staging of cervical cancer (prospective studies). Two studies contributed data from 111 participants. This figure is described in Chapter 3 (page 60). The pooled positive likelihood ratio was 7.85 (95% confidence interval 4.16, 14.80) to accurately identify the stage of cervical cancer. This ratio was statistically significant and the results were homogenous across the studies.

Figure 33 Meta-analysis of the negative likelihood ratio of ^18^FDG-PET/CT v. histology/biopsy or clinical followup for the staging of cervical cancer (prospective studies)

Figure 33 is a meta-graph of the negative likelihood ratio of 18FDG-PET versus histology/biopsy or clinical followup for the staging of cervical cancer (prospective studies). Two studies contributed data from 111 participants. This figure is described in Chapter 3 (page 60). The pooled negative likelihood ratio was 0.12 (95% confidence interval 0.00, 10.08) to accurately identify the stage of cervical cancer. This ratio is not statistically significant and the results were quite heterogeneous across the studies (p = 0.002, I2 = 90 percent).

Figure 34 shows the estimates of sensitivity and 1-specificity plotted in ROC space for ^18^FDG-PET/CT v. histology/biopsy or clinical followup for the staging of cervical cancer.

Figure 34 Summary ROC plot of ^18^FDG-PET/CT v. histology/biopsy or clinical followup for the staging of cervical cancer (prospective studies)

Figure 33 is a meta-graph of the negative likelihood ratio of 18FDG-PET versus histology/biopsy or clinical followup for the staging of cervical cancer (prospective studies). Two studies contributed data from 111 participants. This figure is described in Chapter 3 (page 60). The pooled negative likelihood ratio was 0.12 (95% confidence interval 0.00, 10.08) to accurately identify the stage of cervical cancer. This ratio is not statistically significant and the results were quite heterogeneous across the studies (p = 0.002, I2 = 90 percent).

##### Summary of the results

Meta-analyses were calculated to evaluate the accuracy of ^18^FDG-PET and ^18^FDG-PET/CT to detect recurrences and identify the staging of cervical cancer (Table 13). It appears that overall ^18^FDG-PET is useful to detect or rule out recurrences, although there is some variation in the magnitude of the likelihood ratios across sites. The findings are consistent across each of the sites of recurrence in terms of being statistically significant, as well as for both prospective and retrospective designs. The consistency may provide some robustness for the overall findings. When ^18^FDG-PET and ^18^FDG-PET/CT were evaluated for staging purposes, we found that the values in the positive and negative LRs were similar for both techniques. Significant results were reported for the positive LR, indicating that both techniques seem to be useful to detect the stage of the disease. The results for the negative LR were not statistically significant and therefore, it appears that a negative result both in ^18^FDG-PET and ^18^FDG-PET/CT is not useful to identify the stage of cervical cancer. The findings were consistent across the different reference standards and study designs (i.e., retrospective v. prospective).

Table 13 Results of meta-analyses of the accuracy of ^18^FDG-PET and ^18^FDG-PET/CT for cervical cancer

PET Purpose | Type of PET | Reference standard | Design | Studies | N | Effect estimate M-H, Random, 95% CI
Recurrences | FDG-PET | Histology/biopsy or clinical followup | P | 3 | 230 | Peritoneum: PLR = 15.75 [5.99, 41.38]; NLR = 0.37 [0.22, 0.60]
Recurrences | FDG-PET | Histology/biopsy or clinical followup | P | 3 | 230 | Bone: PLR = 26.56 [11.21, 62.95]; NLR = 0.22 [0.01, 3.40]
Recurrences | FDG-PET | Histology/biopsy or clinical followup | P | 3 | 230 | Liver/spleen: PLR = 45.89 [14.09, 149.49]; NLR = 0.25 [0.08, 0.82]
Recurrences | FDG-PET | Histology/biopsy or clinical followup | P | 3 | 230 | Lung: PLR = 33.32 [13.85, 80.14]; NLR = 0.22 [0.10, 0.48]
Recurrences | FDG-PET | Histology/biopsy or clinical followup | P | 3 | 230 | MLN: PLR = 15.24 [5.63, 41.27]; NLR = 0.09 [0.02, 0.40]
Recurrences | FDG-PET | Histology/biopsy or clinical followup | P | 3 | 230 | SLN: PLR = 29.06 [12.06, 70.03]; NLR = 0.19 [0.10, 0.36]
Recurrences | FDG-PET | Histology/biopsy or clinical followup | P | 3 | 230 | PALN: PLR = 40.24 [11.60, 139.54]; NLR = 0.12 [0.07, 0.23]
Recurrences | FDG-PET | Histology/biopsy or clinical followup | P | 3 | 230 | PLN: PLR = 41.42 [14.51, 118.25]; NLR = 0.23 [0.08, 0.73]
Recurrences | FDG-PET | Histology/biopsy or clinical followup | P | 3 | 230 | ILN: PLR = 27.92 [12.00, 64.94]; NLR = 0.17 [0.05, 0.60]
Recurrences | FDG-PET | Histology/biopsy or clinical followup | R | 3 | 396 | PLN = 5.33 [2.36, 12.05]
Recurrences | FDG-PET | Histology/biopsy or clinical followup | R | 3 | 396 | NLR = 0.11 [0.04, 0.28]
Staging | FDG-PET | Any reference standard | P | 5 | 325 | PLR = 8.22 [2.59, 26.08]
Staging | FDG-PET | Any reference standard | P | 5 | 325 | NLR = 0.38 [0.12, 1.20]
Staging | FDG-PET | Histology/biopsy | P | 4 | 221 | PLR = 5.79 [1.88, 17.88]
Staging | FDG-PET | Histology/biopsy | P | 4 | 221 | NLR = 0.47 [0.17, 1.32]
Staging | FDG-PET | Histology/biopsy | R | 3 | 236 | PLR = 32.90 [2.89, 375.25]
Staging | FDG-PET | Histology/biopsy | R | 3 | 236 | NLR = 0.41 [0.11, 1.55]
Staging | FDG-PET/CT | Any reference standard | P | 3 | 127 | PLR = 6.89 [3.82, 12.42]
Staging | FDG-PET/CT | Any reference standard | P | 3 | 127 | NLR = 0.28 [0.06, 1.38]
Staging | FDG-PET/CT | Histology/biopsy or clinical followup | P | 2 | 111 | PLR = 7.85 [4.16, 14.80]
Staging | FDG-PET/CT | Histology/biopsy or clinical followup | P | 2 | 111 | NLR = 0.12 [0.00, 10.08]

CI = confidence interval; FDG = fluorodeoxyglucose F18; ILN = inguinal lymph node; M-H = Mantel Hantzel; MLN = mediastinal lymph node; NLR = negative likelihood ratio; P = prospective; PALN = para-aortic lymph node; PET = positron emission tomography; PLN = pelvic lymph node; PLR = positive likelihood ratio; R = retrospective; SLN = supraclavicular lymph node

#### 3.3.2 Diagnostic thinking impact of ^18^FDG-PET and ^18^FDG-PET/CT on physician decision making with respect to diagnosis and management strategy for patients with cervical cancer

Six studies reported on the diagnostic thinking impact of ^18^FDG-PET33,43,44,61 and ^18^FDG-PET/CT. 32,38 Chang et al. 33 evaluated the treatment decision impact of ^18^FDG-PET on disease recurrence of cervical cancer. Consecutive outpatients were prospectively enrolled between February 2001 and January 2003. A historical control group that did not undergo ^18^FDG-PET was used for comparison. Eligible patients had a history of histologically confirmed squamous cell carcinoma, adenocarcinoma, or adenosquamous carcinoma of the uterine cervix and had complete remission after primary treatment or salvage therapy. In addition, patients had elevated serum SCC-Ag levels greater than 2.0 ng/mL over the last 2 weeks of the study, but no evidence of recurrent disease on physical examination, Pap smear, chest X-ray, CT or MRI of the pelvis and abdomen, or histological evaluation. Patients who received cytotoxic therapy within the previous 3 months, were previously diagnosed with malignant disease other than nonmelanoma skin malignancy, or had skin or pulmonary lesions, were ineligible. The study population consisted of 27 females, with a mean age of 53.9 years (range 34.8 to 75.8). The disease stage at initial diagnosis was primarily stage I (44 percent) and II (42 percent). It should be noted that 15 of the patients in this study, who had documented relapse after PET, were also included as a subset of the population in another study by Yen et al., 61 reported below. Although these studies were conducted by the same authors and institutions and have overlap in the patient populations, different outcomes were reported and therefore both studies were included in our review. Final diagnosis was established through histological or cytological confirmation via CT or sonar-guided biopsy before treatment. Laparoscopic or exploratory surgery was performed if it was judged as potentially useful for patient management purposes. Patients with inconsistent findings underwent clinical followup for 6 months. ^18^FDG-PET images were interpreted through visual analysis. Diagnosis and treatment decisions were made by consensus among a multidisciplinary panel.

Of the 17 patients with recurrent disease identified by ^18^FDG-PET, seven received therapy with curative intent, four received palliative chemotherapy, and six received supportive care. One patient with negative PET findings had recurrent disease diagnosed at 2 months of clinical followup; she received palliative therapy. Forty-one percent (7/17) of patients with recurrence based on PET findings received treatment with curative intent, compared to 53 percent (16/30) of patients in the historical control group.

The authors concluded that ^18^FDG-PET is a valuable tool for detecting recurrent disease. ^18^FDG-PET findings enabled the selection of patients for treatment with curative intent and also avoided administering unnecessary treatment to patients with incurable disease. Finally, they concluded that ^18^FDG-PET has the possibility of improving the survival as well as the quality of life in patients with recurrent cervical malignancies.

Overall, the quality of this study was assessed as high. Components that were well reported include selection criteria, choice and execution of reference standard, execution of index test, intermediate test results and withdrawals from the study. The period between the index test and reference standard was sufficiently short to prevent disease progression. Furthermore, a reference standard was applied to all patients, albeit not the same standard across all patients. The spectrum of patients enrolled in the study was only partially described, therefore the possibility of spectrum bias cannot be ruled out. This study is also vulnerable to review bias, as the reference standard was not blinded to the findings of the index test and also, it is unclear whether the interpretation of the index test was blinded to the reference.

A study by Lai et al. 43 examined the treatment decision impact of ^18^FDG-PET for assessing restaging and recurrence of cervical cancer. The study population consisted of 45 females with a median age of 51 years (range 25 to 87) whose initial diagnosis was primarily stage I (33 percent) and II (50 percent). Along with a subset of patients from the study by Chang et al., 33 all patients were also included in the study by Yen et al., 61 reported below. Although these studies were conducted by the same authors and institutions, and the patient populations overlap, different outcomes were reported and therefore both are included in our review. Of the 40 patients included in the analysis, 22 (55 percent) had a change in treatment planning as a result of ^18^FDG-PET findings. Fifteen patients had their management shifted from curative to palliative treatment, while seven continued to be treated with curative intent but had a change in their treatment field or modality. Prior to PET scanning, 23 patients planned to undergo concurrent chemotherapy and radiotherapy (CCRT), 17 planned to undergo surgery, and none were scheduled to receive treatment with palliative intent. After PET, 12 patients received CCRT, 13 received surgery and 15 received treatment with palliative intent. In addition, 11 patients underwent a guided biopsy and three patients underwent exploratory surgery due to the findings of ^18^FDG-PET.

The authors concluded the ^18^FDG-PET is better than CT/MRI in restaging cancer recurrence and may significantly reduce the number of unnecessary salvage attempts compared to conventional assessment. They also concluded that use of ^18^FDG-PET in restaging allows clinicians to offer optimal management of recurrent cervical carcinoma.

The quality of this prospective study was assessed as moderate. The selection criteria were clearly described, as was the choice of reference standard and the execution of both index and reference tests. All test results and study participants were accounted for. The period between the index and reference test was sufficiently short that it is unlikely that disease progressed between tests. The whole sample received disease verification using a reference standard; however, the same reference standard was not used for all patients, raising the possibility of verification bias. There was only a partial description of the spectrum of patients included in the study. Finally, it was unclear whether the index test or the reference standard was interpreted while blind to other test results. Due to the lack of clarity in reporting, it is uncertain to what degree review bias may have affected the study findings.

Lin et al. 44 prospectively investigated the benefit of adding ^18^FDG-PET to the diagnostic workup in patients with histologically documented re-recurrent cervical cancer after curative salvage or unexplained elevations in tumor markers. The study sample consisted of 26 females with a median age of 56 years. The disease stage at initial diagnosis was mainly stage I (42 percent) and II (38 percent). Of the 26 patients, 24 had a second recurrence, and two had a third recurrence. The median time between salvage therapy and documented re-recurrence was 12.8 months. ^18^FDG-PET had a positive clinical impact on 12 patients (46 percent). Among these, nine were changed from curative to palliative treatment and three had an isolated in field failure successfully resected due to ^18^FDG-PET. In contrast, ^18^FDG-PET led to unnecessary and invasive additional procedures, such as biopsies, in four patients. As a result of these additional procedures, ^18^FDG-PET was stated to have had an overall negative impact in the management of two patients. The authors concluded that ^18^FDG-PET may facilitate the selection of suitable management strategies for individual patients with re-recurrent cervical cancer.

This prospective study was assessed as being of high quality. Both the selection criteria and choice of reference standard were clearly described, and all test results and study participants were accounted for. The period between the index and reference test was short enough that it is unlikely that disease progressed between tests. The whole sample received disease verification using a reference standard; however, the same reference standard was not used for all patients, raising the possibility of verification bias. The execution of the reference test was well described and the execution of the index test was partially described. There was insufficient detail in reporting the recruitment of patients into the study; therefore it is uncertain whether spectrum bias may have occurred. Finally, the index test results were interpreted without knowledge of the results of the reference standard; however, it is unclear whether the interpretation of the reference standard was also blinded. Therefore, it remains unclear whether review bias may have affected the results of this study.

Yen et al. 61 investigated the treatment decision impact of ^18^FDG-PET for assessing the recurrence of cervical cancer. A total of 55 patients were enrolled from two separate prospective studies examining the role of ^18^FDG-PET in cervical cancer patients. There were 40 patients who had documented treatment failure (Lai et al. 43) and 15 patients with unexplained elevated tumor marker squamous cell carcinoma antigen or carcinoembryonic antigen serum level (Chang et al. 33). The median age of patients was 51 years (range 25 to 86). Forty-five percent of patients had initial stages of Ib or IIa, while 55 percent had stages between IIb and IVa.

Of the 55 enrolled patients, 36 (65 percent) had their treatment plans modified based on the findings of ^18^FDG-PET, while 19 (35 percent) were treated according to their pre-PET plan. Among these 36 patients, nine (25 percent) had treatment that remained curative in intent although the field or modality of radiation changed, while 27 (75 percent) received palliative therapy. Three of the nine patients whose treatment was changed were downstaged.

A prognostic scoring system was used to categorize patients as having low, moderate or high risk of mortality. Based on the findings of ^18^FDG-PET, 10 patients in the low-risk group were changed to palliative treatment, while 17 stayed at curative treatment (seven with changes in treatment plan, 10 with no changes). In the intermediate-risk group, 12 patients were changed to palliative care, and seven stayed on curative therapy (two with changes in treatment plan, five with no changes). Five patients were changed to palliative treatment in the high risk group, whereas one patient stayed on curative treatment.

The authors concluded that ^18^FDG-PET is useful in the management of recurrent cervical cancer because it allows for a more precise restaging than CT or MRI. ^18^FDG-PET may offer maximal benefit by identifying patients suitable for therapy with precise restaging information.

This prospective study was assessed to be of moderate quality. The selection criteria and choice of reference standard were clearly described, and all test results and study participants were accounted for. The time interval between the index and reference test was sufficiently brief that it is unlikely that disease progressed between tests. The whole sample received disease verification using a reference standard; however, the same reference standard was not used for all patients, raising the possibility of verification bias. The execution of both the index and reference standard was only partially described. In addition, it was unclear whether there was blind interpretation of the tests, which may have introduced review bias. Finally, there was lack of clarity in the description of how patients were recruited into the study, creating the potential for spectrum bias.

The study by Bjurberg et al. 32 evaluated the treatment decision and diagnostic testing impact of ^18^FDG-PET for assessment of staging and restaging of cervical cancer. This prospective study enrolled 42 patients with biopsy-proven cervical cancer that were included in three sub-groups for analysis: 1) early disease, followup after surgical treatment (n = 10), FIGO stage Ia:2-IIa; 2) locally advanced disease scheduled for radical radiotherapy (n = 17), FIGO stage Ib:2-IVb; and 3) relapsing disease (n = 15). The mean age of the patients in the three groups was 38.8 years, 55.5 years and 50.3 years, respectively. Changes in treatment management were reported in groups 2) and 3). Of the 17 patients in group 2), four had their treatment strategy changed following ^18^FDG-PET detection of new metastases (24 percent). In the 15 patients from group 3), three cases were assessed as benign by ^18^FDG-PET imaging. Subsequent followup testing verified that ^18^FDG-PET had correctly identified the patients to be free from recurrent disease. ^18^FDG-PET led to a change in the treatment plan for three of the 12 patients assessed as positive for recurrent disease (25 percent). Additional diagnostic testing was performed in six of the 12 recurrent cases.

The authors concluded that ^18^FDG-PET provided detail about the extent of disease, which contributed to the restaging and appropriate management of the patients with locally advanced or recurrent cervical cancer. However, they felt that there was no added value to patient management when ^18^FDG-PET was used in followup for patients with early stage disease. They based this statement on their current results, and pointed out that the followup period was short and the number of patients was very small.

This prospective study was assessed to be of moderate quality. The selection criteria and choice of reference standard were clearly described, and all test results and study participants were accounted for. The whole sample received disease verification using a reference standard; however, the same reference standard was not used for all patients, raising the possibility of verification bias. The time interval between the index and reference test was not clearly reported, and the execution of both the index and reference standard was only partially described. It was unclear whether there was blind interpretation of the tests, which may have introduced review bias.

In a retrospective review of the medical records of 52 women, Chung et al. 38 examined the treatment decision impact of ^18^FDG-PET/CT on assessing the recurrence of cervical cancer. The mean age of patients was 53 years (range 32 to 77), with primarily stage I (50 percent) and II (40 percent) cancer. Treatment management was altered on the basis of ^18^FDG-PET/CT findings for 12 patients (23 percent). In three patients, previously unplanned treatment was initiated, while in five changes were made to the previously planned therapeutic approach. For the remaining three patients, previously planned diagnostic procedures were not required. In addition, ^18^FDG-PET/CT provided valuable information for 12 patients by identifying the exact location of lymph nodes (five patients), showing precise location of pelvic wall or bone infiltration (five patients), and the exact location of distant metastases. In nine patients, ^18^FDG-PET/CT guided additional invasive diagnostic procedures.

The authors also reported the prognostic outcomes of patients undergoing ^18^FDG-PET/CT. The 2-year disease-free survival rate of patients who had negative ^18^FDG-PET/CT results was significantly better than for patients who tested positive on ^18^FDG-PET/CT (85 percent v. 10.9 percent, p = 0.002).

The authors concluded that ^18^FDG-PET/CT provided good anatomical and functional localization of suspicious lesions. The superior diagnostic interpretation of ^18^FDG-PET/CT had a positive impact on clinical management, treatment planning and on disease-free survival rate. The quality of this retrospective study was rated moderate. The greatest methodological weaknesses included only partial reporting of the spectrum of patients enrolled and lack of clarity on the period between the index and reference standard. Although the whole sample received disease verification using a reference standard, the same reference standard was not used for all patients, raising the possibility of verification bias. The selection criteria and choice of reference standard were clearly described, and all test results and study participants were accounted for.

#### 3.3.3 ^18^FDG-PET and ^18^FDG-PET/CT as part of a management strategy in cervical cancer

Two studies33,43 evaluated the impact of ^18^FDG-PET as part of a management strategy on patient-centered outcomes. Chang et al. 33 compared the mean overall survival between a group that underwent ^18^FDG-PET and a historical control group. The followup times were similar for both groups (11.9 months and 14 months, respectively). Characteristics of the population and ^18^FDG-PET have been described above. Compared to the historical control group, overall survival improved for patients who had ^18^FDG-PET as part of their diagnostic work-up (^18^FDG-PET group = 22.0 months [95% CI: 17.3 to 26.7 months]; historical cohort: 12.7 months [95% CI: 7.9 to 17.5; p = 0.02]. This was an observational study; therefore, reliable conclusions cannot be made regarding the effectiveness of ^18^FDG-PET as part of a management strategy to improve patients’ overall survival. It is unknown whether factors other than the exposure to the intervention (i.e., ^18^FDG-PET) are equally distributed among the groups.

The study by Lai et al. 43 compared the 2-year overall survival rate for patients who underwent ^18^FDG-PET as part of their diagnostic work-up compared to a group of patients who did not undergo disease restaging with PET. Characteristics of the population and ^18^FDG-PET have been described above. All seven patients who continued with curative treatment, but had their treatment field altered, remained alive. In the primary surgery group, the 2-year overall survival rate was significantly greater among the ^18^FDG-PET group compared to the historical cohort whose disease was restaged without ^18^FDG-PET (hazard ratio: [HR]: 0.21; 95% CI: 0.05-0.83; p = 0.02). Among patients receiving primary RT or CCRT, there was no difference between the two groups in 2-year overall survival (HR: 0.99; 95% CI: 0.53, 1.85; p = 0.99). The authors reported that clinical characteristics were similar for study participants and historical control patients in the primary surgery group and they suggested that it was unlikely that the observed benefit in overall survival probably were due to other prognostic factors. This was an observational study and therefore, conclusions that can be made about the effectiveness of ^18^FDG-PET on patient-survival are limited.

##### Summary of the results

There were six studies of moderate to high methodological quality that evaluated the use of ^18^FDG-PET33,43,44,61 or ^18^FDG-PET/CT32,38 to assess the staging/restaging32,43 or recurrence33,38,44,61 of cervical cancer. The findings were generally positive with authors concluding that both ^18^FDG-PET and ^18^FDG-PET/CT assisted in guiding the management strategy by allowing for more precise restaging. Notably, the use of ^18^FDG-PET and ^18^FDG-PET/CT most often altered the management course from curative to palliative care, thus avoiding unnecessary treatment. Further, two prospective studies33,43 found improved survival among patients who had ^18^FDG-PET as part of their management strategy.

Table 14 provides a summary of the main findings and the types of bias that affected the evidence on the diagnostic thinking impact and effect on patient-centered outcomes of ^18^FDG-PET and ^18^FDG-PET/CT for cervical cancer.

Table 14 Main findings and types of bias that affected the evidence on the diagnostic thinking impact and effect on patient-centered outcomes of ^18^FDG-PET and ^18^FDG-PET/CT for cervical cancer

Study | Results of FDG-PET imaging on patient diagnosis, treatment and outcomes | Types of bias
Bjurberg 2007^32^ Study type: Prospective | Management decision: Treatment and diagnostic testing impact Treatment strategy changed due to identification of new metastasis for 4/17 cases (24%) PET did not confirm clinical suspicion of recurrence. PET deemed to be true negative on followup 3/15 cases; Treatment strategy changed for 3/12 positive recurrence cases (25%) Additional diagnostic testing occurred in 6/12 positive recurrence cases | Spectrum bias (unclear) Selection bias (unclear) Verification bias (>1 RS) Review bias (PET; unblinded; RS, unblinded)
Chang 2004^33^ Study type: Prospective | Management decision: Treatment Treatment plan changed in 17/27 cases (63%) Curative therapy (n = 7) Palliative chemotherapy (n = 4) Supportive care (n = 6) 7/18 (39%) patients with recurrence received curative therapy based on PET, compared to 53% (16/30) in historical control group Patient-centered outcomes: Mean overall survival PET group: 22 mo. (95% CI: 17.3, 26.7) v. historical control: 12.7 mo. (95% CI: 7.9,17.5) | Spectrum bias (unclear) Verification bias (>1 RS) Review bias (PET; unclear if blinded; RS, unblinded)
Chung 2007^38^ Study type: Retrospective | Management decision: Treatment and diagnostic testing impact Treatment management change in 12 patients (23%): Initiated previously unplanned treatment (n = 4), Changed previously planned therapeutic approach (n = 5) Eliminate previously planned diagnostic procedure (n = 3) PET/CT guided additional invasive diagnostic procedures (n = 9). | Spectrum bias (unclear) Selection bias (unclear) Disease progression bias (unclear) Verification bias (>1 RS) Review bias (RS, unclear)
Lai 2004^43^ Study type: Prospective | Management decision: Treatment and diagnostic testing impact Treatment plan change in 22/40 patients (55%): Shifted from curative to palliative treatment (n = 15), Curative treatment continued; altered treatment field or modality (n =7) Diagnostic testing impact due to PET findings in 14 patients: Additional guided biopsy (n = 11); exploratory surgery (n = 3) Patient-centered outcomes Patients treated with altered treatment field remained alive (n = 7). Primary surgery group, had a significant 2-yea overall survival rate in PET group compared to those restaged without PET. Patients receiving primary RT or CCRT had no significant differences among the two groups. | Spectrum bias (unclear) Verification bias (>1 RS) Review bias (PET and RS; unclear if blinded)
Lin 2006^44^ Study type: Prospective | Management decision: Treatment PET had positive clinical impact on 12/26 patients (46%); Changed from curative to palliative treatment (n = 9), Isolated in field failure successfully resected due to PET (n = 3) PET led to unnecessary and invasive additional procedures (e.g., biopsies) (n = 4) PET stated to have had overall negative impact in management (n = 2) | Spectrum bias (unclear) Verification bias (>1 RS) Review bias (RS; unclear if unclear if blinded)
Yen 2004^61^ Study type: Prospective | Management decision: Treatment Treatment plans modified based on PET in 36/55 patients (65%): Field or modality of radiation changed (n = 9) Changed from curative to palliative therapy (n = 27) | Spectrum bias (unclear) Verification bias (>1 RS) Review bias (PET and RS; unclear if blinded)

CCRT = concurrent chemotherapy and radiotherapy; CI = confidence interval; FDG = fluorodeoxyglucose F18; mo = months; PET = positron emission tomography; RS = reference standard; RT = radiotherapy

## 4 Kidney Cancer

### 4.1 Background

Approximately 54,390 new cases of kidney and renal pelvis cancer will be diagnosed in the United States during 2008; 60 percent of these cases will occur in men. 133 The National Cancer Institute indicates that kidney cancer has been increasing at a rate of 2 percent per year for the last 65 years. Mortality has also increased, but to a lesser degree than incidence, during this same time period. 133 An estimated 13,101 deaths will be caused by kidney cancer in 2008. 133 Native-Americans suffer the highest rates of kidney cancer (20.9 and 10.0 cases per 100,000 for men and women respectively); however, African-Americans also show higher rates of cancer incidence than what is observed among Caucasian-Americans. 146 The median age of onset for renal cancer is 65 years. 133 In Europe, 5-year survival is 71 percent in individuals under 45 years of age where kidney cancer is rare but decreases to 45 percent in patients over 74 years in Europe. 147

The early diagnosis of renal carcinoma is hampered by the observation that tumors can grow quite large before the patient exhibits any symptoms. Pain, hematuria and flank masses have been traditional symptoms but these appear in only 9 percent of patients and are often indicative of advanced disease. 147 Hyprochromic anaemia, fever, cachexia, fatigue, and weight loss may also be symptomatic of renal carcinoma. 147 Approximately 30% of patients have with metastatic disease. 147

Specific early screening programs for kidney cancer are not realistic as the populations that would be targeted are too large and currently there is no evidence to support a population-based screening program. 147 Small renal masses are detected through routine imaging with increasing frequency, but imaging is not specific enough to accurately discriminate between benign and malignant tumors. Local symptoms are considered the best predictive tool in determining malignancy. 146

CT seems to be an effective tool in the staging of renal carcinomas with a sensitivity of 90 percent for small tumors and 95 percent for tumors larger then 3 centimeters. 147 Ultrasonography is often used as well, with sensitivity of 60 percent for detecting small tumors and 85 percent for larger tumors. 147 MRI has not been shown to be effective in characterising tumors in patients with renal carcinoma but may still be employed to provide information about the tumor involvement with the vena cava or when surgical removal of tumors is being planned. 147 Staging of renal carcinoma is commonly done using the Robson classification scheme within the United States. While this staging system is uncomplicated, the main weakness is that it combines stages that may have widely varied survival prognoses. The Robson stages of renal carcinoma are outlined below in Table 15.

Table 15 Robson stages of renal cancer Stage Description

Stage | Description
I | Renal carcinoma is localized to the kidney only
II | Cancer extends to renal capsule but is confined to the Gerota’s fascia
III | Tumor is associated with the inferior vena cava or renal vein (stage IIIa) or local hiliar lymph notes (stage IIIb)
IV | Cancer has spread to other local organs or distant sites

Taken from Corgna et al. 147

The TNM classification offers more complete stratification of patients and a more accurate assessment of their prognosis. In TNM classification, the T refers to the tumor size and whether or not it has spread to adjacent tissues, the N represents whether or not there has been spread to the lymph nodes, and the M indicates whether the cancer has metastasised.

Surgical resection is the primary method of curative therapy for kidney cancer. Radical nephrectomy is the main operation performed, but new organ-sparing approaches such as laparoscopic nephrectomy are used increasingly. 146,147 Palliative surgery is also frequent. 147 There are no standard chemotherapy or immunotherapy treatments for renal cell carcinoma. 147 Radiation therapy in patients with metastatic disease may resolve symptoms in some patients. 147

### 4.2 Importance of Key Questions in the Clinical Management of Kidney Cancer

Survival is very much related to the stage of cancer when it is diagnosed. The ability to detect and characterize renal masses more accurately and to stage malignant renal tumors is crucial for the management of patients. The identification of a single or several metastatic lesions can lead to differing therapeutic approaches (e.g., surgery or systemic treatment). If detected early, renal tumors can be treated with alternatives other than standard radical nephrectomy, such as minimally invasive surgery and partial nephrectomy. Although solid renal masses are considered malignant tumors, benign solid renal masses are not uncommon. Morphological imaging methods present several diagnostic problems in differentiating between benign and malignant solid renal tumors. They also show some limitations in evaluating kidney cancer with regard to local spread and distant disease. Improving the diagnostic yield of these investigations while precluding the need for obtaining a tissue diagnosis would have obvious implications in management. The role of ^18^FDG-PET in the diagnosis, staging, and management of kidney cancer has not been clearly defined.

### 4.3 Results

Eight studies64-71 provided evidence on the use of ^18^FDG-PET. We did not find studies that reported on the use of ^18^FDG-PET/CT for kidney cancer. All eight studies evaluated the diagnostic accuracy of ^18^FDG-PET for kidney cancer. Three studies67,69,70 reported on the diagnostic thinking impact of ^18^FDG-PET. None of the studies evaluated the impact of ^18^FDG-PET or ^18^FDG-PET/CT as part of a management strategy on patient-centered outcomes. No economic evaluations on the use of ^18^FDG-PET or ^18^FDG-PET/CT for kidney cancer were identified. Characteristics of the populations, conditions of ^18^FDG-PET administration, interpretation of results and methodological quality of the studies are summarized in Appendices D to J.

#### 4.3.1 Diagnostic accuracy of ^18^FDG-PET in kidney cancer

##### Characteristics of the studies

Eight studies (three prospective, 64,65,67 five retrospective66,68-71) evaluated the diagnostic accuracy of ^18^FDG-PET. One study used ^18^FDG-PET for initial staging, 67 one for primary diagnosis, 65 one for restaging, 68 one for initial staging and recurrences, 71 and four used ^18^FDG-PET for both primary diagnosis and initial staging. 64,66,69,70 The studies contained a total of 250 patients with sample sizes ranging from 15 to 66 participants. Participant ages ranged from 23 to 87 years. In five studies ^18^FDG-PET was compared to histology/biopsy or clinical followup as the reference standard; 64,67-70 in the three remaining studies histology/biopsy was used exclusively as the reference standard. 65,66,71 One study reported the mean time between last treatment and ^18^FDG-PET as 3 to 24 months. 68 Three studies used a fixed dose of ^18^FDG (1.5 mCi, 67 395.9 MBq, 71 370 MBq66); two studies used a weight-based dose (2.516 to 5.2 MBq/kg70 and 2 MBq/kg64); two studies reported a dose range (370 to 444 MBq65 and 370 to 555 MBq68); and one study did not report on dosing. 69 The time between ^18^FDG injection and PET scan was 45 minutes, 69 50 minutes, 66 60 minutes, 64,65,67,70 or ranged between 45 to 60 minutes. 68,71 Patients fasted for four hours, 67,70 six hours, 64-66 and overnight. 71 Three studies measured maximum glucose levels of 135 mg/Dl, 65 140 mg/dL70 and 150 mg percent66 before administration of ^18^FDG-PET. Methods of interpretation were qualitative in five studies64,65,68,69,71 and both qualitative and quantitative in two studies. 66,70 Scans were interpreted qualitatively using visual analysis in all studies. 64-66,68-71 Both studies66,70 used SUV values for the quantitative interpretation of the PET images with one study reporting the criterion for abnormality as an SUV > 2.5 g/mL. 66

##### Comparisons

Comparisons for which data were considered for meta-analysis are summarized in Table 16. Pooled data were obtained to evaluate the accuracy of ^18^FDG-PET for the primary diagnosis and staging of kidney cancer. Individual study data are summarized in Appendix D.

Table 16 Summary of comparisons considered for meta-analyses of the accuracy of ^18^FDG-PET for kidney cancer

Indication | Studies | Design | Type of PET | Reference standard | Meta-analysis
Primary diagnosis and staging | Aide 2003^64^ | P | FDG-PET | Histology/biopsy or clinical followup | 1. FDG-PET v. any reference standard (R studies) 66,69,70 2. FDG-PET v. histology/biopsy or clinical followup (R studies) 69,70
Primary diagnosis and staging | Chang 2003^66^ | R | FDG-PET | Histology/biopsy | 1. FDG-PET v. any reference standard (R studies) 66,69,70 2. FDG-PET v. histology/biopsy or clinical followup (R studies) 69,70
Primary diagnosis and staging | Kang 2004^69^ | R | FDG-PET | Histology/biopsy or clinical followup | 1. FDG-PET v. any reference standard (R studies) 66,69,70 2. FDG-PET v. histology/biopsy or clinical followup (R studies) 69,70
Primary diagnosis and staging | Kumar 2005^70^ | R | FDG-PET | Histology/biopsy or clinical followup | 1. FDG-PET v. any reference standard (R studies) 66,69,70 2. FDG-PET v. histology/biopsy or clinical followup (R studies) 69,70
Staging and recurrences | Majhail 2003^71^ | R | FDG-PET | Histology/biopsy | No
Primary diagnosis | Ak 2005^65^ | P | FDG-PET | Histology/biopsy | No
Restaging | Jadvar 2003^68^ | R | FDG-PET | Histology/biopsy or clinical followup | No
Staging | Dilhuydy 2006^67^ | P | FDG-PET | Histology/biopsy or clinical followup | No

FDG = fluorodeoxyglucose F18; P = prospective; PET = positron emission tomography; R = retrospective

###### 1 ^18^FDG-PET for the primary diagnosis and staging of kidney cancer

Reference standard: any; retrospective studies. A meta-analysis of retrospective studies was conducted to evaluate the accuracy of ^18^FDG-PET for the primary diagnosis and staging of kidney cancer. Three retrospective studies66,69,70 totaling 42 participants compared ^18^FDG-PET v. any reference standard for the primary diagnosis and staging of kidney cancer. Individual 2x2 table results are presented in Figure 35. Sensitivity ranged from 60 percent69 to 90 percent. 66 Specificity ranged from 80 percent66 to 100 percent. 69,70

Figure 35 Results from 2x2 tables of individual retrospective studies of ^18^FDG-PET v. any reference standard for the primary diagnosis and staging of kidney cancer

We found that ^18^FDG-PET had a pooled positive LR of 3.95 (95% CI = 1.14, 13.73) and a pooled negative LR of 0.30 (95% CI = 0.12, 0.79) to help in the diagnosis and staging of kidney cancer (Figures 36 and 37). Both the positive and negative LRs were statistically significant and the results were fairly homogeneous across the studies. Therefore, ^18^FDG-PET seems to be helpful in the primary diagnosis and detection of staging of kidney cancer.

Figure 36 Meta-analysis of the positive likelihood ratio of ^18^FDG-PET v. any reference standard for the primary diagnosis and staging of kidney cancer (retrospective studies)

Figure 36 is a meta-graph of the positive likelihood ratio of 18FDG-PET versus any reference standard for the primary diagnosis and staging of kidney cancer (retrospective studies). Three studies contributed data from 42 participants. This figure is described in Chapter 4 (page 75). The pooled positive likelihood ratio to rule in disease was of 3.95 (95% confidence interval 1.14, 13.73). The ratio was statistically significant and results were fairly homogeneous across studies.

Figure 37 Meta-analysis of the negative likelihood ratio of ^18^FDG-PET v. any reference standard for the primary diagnosis and staging of kidney cancer (retrospective studies)

Figure 37 is a meta-graph of the negative likelihood ratio for 18FDG-PET versus any reference standard for the primary diagnosis of kidney cancer (retrospective studies). Three studies contributed data from 42 participants. This figure is described in Chapter 4 (page 75). The pooled negative likelihood ratio to rule out disease was 0.30 (95% confidence interval 0.12, 0.79). This ratio was statistically significant and results were fairly homogenous across studies.

Figure 38 shows the estimates of sensitivity and 1-specificity plotted in ROC space for ^18^FDG-PET v. any reference standard for the primary diagnosis and staging of kidney cancer based on retrospective studies.

Figure 38 Summary ROC plot of ^18^FDG-PET v. any reference standard for the primary diagnosis and staging of kidney cancer (retrospective studies)

Figure 38 is a summary receiver operating characteristics plot of FDG-PET versus any reference standard for the primary diagnosis and staging of kidney cancer (retrospective studies). This figure shows the paired estimates of sensitivity and 1-specificity for each of the three included studies. Specificity is recorded on the X-axis and sensitivity is recorded on the Y-axis. The curve appears in the upper left hand corner (page 75).

Reference standard: histology/biopsy or clinical followup; retrospective studies. Two retrospective studies69,70 totaling 27 participants provided data for a subgroup analysis of the accuracy of ^18^FDG-PET when histology/biopsy or clinical followup were used as the reference standard for the primary diagnosis and staging of kidney cancer. Individual 2x2 table results are presented in Figure 39. Sensitivities were 60 percent69 and 89 percent; 70 specificity was 100 percent in both studies.

Figure 39 Results from 2x2 tables of individual retrospective studies of ^18^FDG-PET v. histology/biopsy or clinical followup for the primary diagnosis and staging of kidney cancer

When histology or biopsy was considered as the reference standard, ^18^FDG-PET had a pooled positive LR of 3.48 (95% CI = 0.60, 20.15) and a pooled negative LR of 0.42 (95% CI = 0.21, 0.84) to help in the diagnosis and staging of kidney cancer (Figures 40 and 41). The positive LR was not statistically significant and therefore, is inconsistent with a previous meta-analysis of three studies (see Figure 38), suggesting that no firm conclusions can be drawn. The negative LR was statistically significant and homogeneous across the studies and therefore, it can be said that ^18^FDG-PET may be useful to rule out a diagnosis of kidney cancer.

Figure 40 Meta-analysis of the positive likelihood ratio of ^18^FDG-PET v. histology/biopsy or clinical followup for the primary diagnosis and staging of kidney cancer (retrospective studies)

Figure 40 is a meta-graph of the positive likelihood ratio versus histology/biopsy or clinical followup for primary diagnosis and staging of kidney cancer (retrospective studies). Two studies contributed data from 27 participants. This figure is described in Chapter 4 (page 77). The pooled positive likelihood ratio was 3.48 (95% confidence interval 0.60, 20.15) to accurately stage the disease. The positive likelihood ratio was not statistically significant.

Figure 41 Meta-analysis of the negative likelihood ratio of ^18^FDG-PET v. histology/biopsy or clinical followup for the primary diagnosis and staging of kidney cancer (retrospective studies)

Figure 41 is a meta-graph of the positive likelihood ratio versus histology/biopsy or clinical followup for primary diagnosis and staging of kidney cancer (retrospective studies). Two studies contributed data from 27 participants. This figure is described in Chapter 4 (page 77). The pooled negative likelihood ratio was 0.42 (95% confidence interval 0.21, 0.84) to accurately stage disease. This ratio was statistically significant and homogeneous across the studies.

Figure 42 shows the estimates of sensitivity and 1-specificity plotted in ROC space for ^18^FDG-PET v. histology/biopsy or clinical followup for the primary diagnosis and staging of kidney cancer based on retrospective studies.

Figure 42 Summary ROC plot of ^18^FDG-PET v. histology/biopsy or clinical followup for the primary diagnosis and staging of kidney cancer (retrospective studies)

Figure 42 is a summary receiver operating characteristics plot of 18FDG-PET versus histology/biopsy or clinical followup for the primary diagnosis and stage of kidney cancer (retrospective studies). This figure shows the paired estimates of sensitivity and 1-specificity for both of the included studies. Specificity is recorded on the X-axis and sensitivity is recorded on the Y-axis. The curve appears in the upper left hand corner (page 77).

##### Summary of the results

Meta-analyses were calculated to evaluate the accuracy of ^18^FDG-PET for the diagnosis and staging of kidney cancer (Table 17). When ^18^FDG-PET was compared against any reference standard, retrospective studies reported a statistically significant result for the positive LR. However, when a subset of these studies, which used histology/biopsy or clinical followup as the reference standard, were considered, the pooled results were not statistically significant. Since the non-significant positive LR in the latter meta-analysis may be due to insufficient sample size rather than the utility of the test, no conclusions can be drawn regarding the ability of ^18^FDG-PET to rule in a diagnosis or stage of kidney cancer. The pooled negative LRs were similar and statistically significant in both meta-analyses, suggesting that ^18^FDG-PET may be useful to rule out a diagnosis of kidney cancer or particular stages of the disease.

Table 17 Results of meta-analyses of the accuracy of ^18^FDG-PET for kidney cancer

PET Purpose | Type of PET | Reference standard | Design | Studies | N | Effect estimate M-H, Random, 95% CI
Primary diagnosis and staging | FDG-PET | Any reference standard | P | 3 | 42 | PLR = 3.95 [1.14, 13.73]
Primary diagnosis and staging | FDG-PET | Any reference standard | P | 3 | 42 | NLR = 0.30 [0.12, 0.79]
Primary diagnosis and staging | FDG-PET | Any reference standard | R | 2 | 27 | PLR = 3.48 [0.60, 20.15]
Primary diagnosis and staging | FDG-PET | Any reference standard | R | 2 | 27 | NLR = 0.42 [0.21, 0.84]

CI = confidence interval; FDG = fluorodeoxyglucose F18; M-H = Mantel Hantzel; NLR = negative likelihood ratio; P = prospective; PET = positron emission tomography; PLR = positive likelihood ratio; R = retrospective

#### 4.3.2 Diagnostic thinking impact of ^18^FDG-PET on physician decision making with respect to diagnosis and management strategy for patients with kidney cancer

Three studies67,69,70 evaluated the use of ^18^FDG-PET on physician decision-making with regard to patient management and diagnostic work-up of renal cell carcinomas (RCC). The studies considered patients with suspected but undiagnosed primary RCCs and patients with recurrent or metastatic disease. The imaging by ^18^FDG-PET was used for both initial diagnostic and staging purposes.

Dilhuydy et al. 67 investigated the treatment decision impact of ^18^FDG-PET imaging on the restaging and management of patients suffering from RCC with metastatic disease. Participants included 24 patients who underwent a total of 26 PET scans. Overall, there were five changes (21 percent) to the management strategy. Evaluation of the changes to clinical management was subdivided by the type of assessment the patients were undergoing. There were 20 ^18^FDG-PET scans in patients to assess limited or solitary tumor sites. Of these, the treatment plan was modified after ^18^FDG-PET in only three patients (15 percent). Additionally, five ^18^FDG-PET scans were performed in patients who appeared to have had a complete response to treatment. Of these, two scans were positive for ^18^FDG uptake, prompting a change in therapeutic management. Thus, the impact of the ^18^FDG-PET imaging appeared to be greater in the assessment of patients thought to have complete response following treatment. However, the number of patients in this group was small, so this result should be interpreted with caution. The five changes resulting from the ^18^FDG-PET imaging were: from observation to surgery (n = 2) or immunotherapy (n = 2) and from surgery to immunotherapy (n = 1).

The authors concluded that positive ^18^FDG-PET images may lead to modification of the treatment decisions made; however, negative ^18^FDG-PET results should not alter treatment planning. Particular value of ^18^FDG-PET imaging was found in the identification of distant metastatic sites, justifying the addition of complementary treatment in addition to surgery.

This retrospective study was determined to be of moderate quality. The choice and administration of the independent reference standard were well reported. Additionally, equivocal results were reported, and there was satisfactory explanation for withdrawals. However, given the retrospective nature of the study, interpretation of the reference standard was not blinded, which may have introduced review bias. Furthermore, there was an incomplete description of the spectrum of included patients and the inclusion criteria, making it difficult to rule out selection bias. There was more than one reference test, which may have introduced verification bias.

Kang et al. 69 evaluated the accuracy of ^18^FDG-PET imaging on a mixed population of patients undergoing initial diagnosis and staging or restaging of RCC. The subsequent impact on treatment decisions and diagnostic workup was assessed. This was a retrospective review of 66 consecutive patients who underwent 90 ^18^FDG-PET scans. The sample included two types of patients: those with suspicion of primary RCC who had not undergone nephrectomy (n = 17, 17 scans); and for restaging of patients with RCC who had undergone nephrectomy (n = 54, 73 scans). A total of 17 patients underwent multiple ^18^FDG-PET scans. The treatment plan was revised in 12 cases (13 percent) of the total 90 scans in this study. There was minor impact on the additional diagnostic work-up in one case in which the ^18^FDG-PET scan led to the order for an abdominal MRI to confirm the presence of a primary RCC. Changes made in treatment plans included two cases in which surgery was indicated as a result of ^18^FDG-PET imaging. Additionally, in nine cases the ^18^FDG-PET analyses lead to reinterpretation of conventional imaging. Within the subgroup of 17 patients with no history of nephrectomy, two were accurately identified as having benign cysts by ^18^FDG-PET, however, 6/15 (40 percent) disease positive individuals were not captured by ^18^FDG-PET imaging, yielding to a lower sensitivity than conventional CT imaging. Of the patients with a history of disease who had undergone nephrectomy, ^18^FDG-PET detected 64 percent of all soft tissue metastasis and 79 percent of bone metastasis. For 87 of the 90 ^18^FDG-PET studies, there was at least one associated conventional image available (e.g., CT scan). When compared to the associated conventional images, ^18^FDG-PET studies showed a lack of sensitivity for detection of metastatic lesions. ^18^FDG-PET imaging failed to identify all lesions detected by conventional imaging in 39 scans (45 percent). However, ^18^FDG-PET images did identify previously unknown lesions in 11 scans (13 percent).

The prognostic value of ^18^FDG-PET imaging was assessed by following the progression of metastatic lesions present on ^18^FDG-PET imaging prior to immunotherapy. Of 31 lesions which progressed, 25 (81 percent) had been positively identified on the initial ^18^FDG-PET scan. There were 42 lesions that remained stable, of which only 28 (67 percent) had been positive on the initial ^18^FDG-PET scan.

Overall, the authors concluded that although ^18^FDG-PET imaging was more specific than conventional imaging, its use was limited by its low sensitivity for detecting RCC. It was thought that ^18^FDG-PET imaging holds value as a complementary tool, particularly in suspicious or equivocal cases.

This retrospective study was assessed as being of moderate quality. The spectrum of patients and selection criteria, the choice and administration of the independent reference standard, and intermediate test results were all well reported. Additionally, all cases were verified by a reference standard and there were no withdrawals. There was inadequate reporting on some aspects, including detail about the execution of the ^18^FDG-PET scan and reference tests. Due to the retrospective design of the study, the reference standard did not undergo blind interpretation, thus leading to the possibility of review bias. There was no one reference standard; rather a combination of methods was used (histological or clinical followup), which may have introduced verification bias in the validation of true disease status.

Kumar et al. 70 retrospectively evaluated the impact of ^18^FDG-PET imaging on a mixed population of patients with suspected or known RCC who were undergoing assessment for diagnosis and staging of their disease. The impact on subsequent treatment management was assessed. Twenty-four patients who underwent ^18^FDG-PET imaging were included in this analysis. In the 24 patients, a total of 28 solid renal masses were assessed. There were 10 patients with primary renal tumors and 14 metastatic renal tumors. ^18^FDG-PET results led to changes in 3 of the 10 patients with primary tumors (30 percent). These changes included avoidance of surgery in the case of a mass determined to be benign, proceeding with surgery in a case where lung metastasis was ruled out, and cancellation of surgery due to detection of unsuspected bone metastases. There were no changes in treatment management reported for the 14 metastatic renal tumors imaged by ^18^FDG-PET.

The authors concluded that ^18^FDG-PET was useful as a complementary modality to CT scans for staging and treatment management of primary malignant renal tumors, as well as for characterization of renal masses resulting from metastases of other primary cancers. They identified that the study was limited by the population, as the included cases had known renal masses previously detected by conventional imaging by CT scan or MRI.

This retrospective study was assessed as being of moderate quality. Methodological strengths included: a clear description of the selection criteria and spectrum of included patients, appropriate choice of reference standard. Additionally, intermediate results were reported and there were no withdrawals. There was inadequate reporting of some aspects, including detail about the execution of the ^18^FDG-PET scan and reference tests. As only patients with known renal masses were included, the generalizability of the study may be limited. The interpretation of the index and reference tests was not reported to be blinded, thus introducing the possibility of review bias. Finally, it is crucial to note that not only was there no single reference standard, but PET imaging also formed a part of the reference standard in some instances. This methodological flaw may have introduced verification bias in the validation of the true disease status.

##### Summary of the results

Three retrospective studies of moderate methodological quality evaluated the use of ^18^FDG-PET67,69,70 on physician decision-making for the initial diagnosis69,70 and staging67,69,70 of kidney cancer. The usefulness of ^18^FDG-PET seems less apparent for kidney cancer; notably, the proportion of cases where management changed as a result of the ^18^FDG-PET findings was generally small. This could be a due to the fact that kidney cancer is not often diagnosed until tumors are large or more advanced. Alternatively, the minimal impact of ^18^FDG-PET results on physician decision-making may result from the small number of studies with small overall number of participants. Moreover, most of the authors recommend ^18^FDG-PET as a complementary tool but one author qualified that it may be most useful in selecting cases (e.g., suspicious or equivocal cases). More work is needed to delineate in what situations ^18^FDG-PET would be most useful. General conclusions cannot be made, since the evidence base is limited, consisting of a small number of retrospective studies with moderate methodological quality.

Table 18 provides a summary of the main findings and the types of bias that affected the evidence on the diagnostic thinking impact of ^18^FDG-PET on kidney cancer.

Table 18 Main findings and types of bias that affected the evidence on the diagnostic thinking impact of ^18^FDG-PET for kidney cancer

Study | Results of FDG-PET imaging on patient diagnosis and treatment | Types of bias
Dilhuydy 2006^67^ Study type: Retrospective | Management decision: Treatment and diagnostic testing impact Management strategy changed 5/24 (21%) Treatment instead of monitoring strategy changed (n = 4): Received surgery (n = 2) or immunotherapy (n = 2) Type treatment altered (n = 1) (surgery instead of immunotherapy) Management changed in 2/5 patients assessed as “complete response ” to prior treatment by conventional CT + bone scans | Spectrum bias (unclear) Selection bias (unclear) Verification bias (>1 RS) Review bias (PET, unblinded; RS, unclear)
Kang 2004^69^ | Management decision: Treatment and diagnostic testing impact 66 patients received 90 PET scans Management strategy changed in 12/90 (13%) Recurrences identified lead to surgery (n = 2) (Treatment); Additional diagnostic by MRI ordered (n = 1) (Diagnostic Imaging); Reinterpretation of previous imaging (n = 9) (Diagnostic Imaging) Prognostic value for immunotherapy: Accuracy of metastatic lesion detection by PET assessed: 81% of PET positive lesions progressed v. 67% of PET negative lesions | Verification bias (>1 RS) Review bias (PET, unblinded; RS, unclear if blinded)
Kumar 2005^70^ | Management decision: Treatment Treatment strategy changed for 3/10 (30%) primary renal tumor cases. No changes were mentioned in the 14 cases of renal cancer metastasis. Thus, overall 3/24 cases changed (13%): -Identified to have a benign mass, and surgery avoided (n = 1) -Unsuspected bone metastasis, radical surgery cancelled (n = 1) -Ruled out lung metastasis, surgery proceeded (n = 1) | Verification bias (>1 RS) (PET, unclear if blinded; RS, unblinded)

CT = computed tomography; FDG = fluorodeoxyglucose F18; MRI = magnetic resonance imaging; PET = positron emission tomography; RS = reference standard

## 5 Ovarian Cancer

### 5.1 Background

Ovarian cancer is the fifth most common malignancy and the fifth leading cause of cancer mortality in American women. It also leads to more deaths than any other gynecological malignancy. 148 In the United States, an estimated 21,650 new cases will be diagnosed and 15,520 women with die from ovarian cancer in 2008. 133 Caucasian-American women experience higher incidence rates than African-American or Asian-American women. 148

Between 1996 and 2004, the 5-year survival rate for women with ovarian cancer in the United States was 45.5 percent. 133 Poor outcomes are associated with the lack of effective methods for prevention and early detection. If diagnosed early, survival rates improve dramatically, to approximately 95 percent. 149 For 80 to 90 percent of women, diagnosis occurs after 40 years of age; less than 1 percent are diagnosed before 20 years of age. 148 The median age at first diagnosis is 62 years. 133

Approximately 90 percent of ovarian cancers are derived from the epithelial cells of the ovaries. 148 Of epithelial ovarian neoplasms, 10 to 20 percent tend to develop into borderline or low malignant potential tumors. Epithelial tumors are divided into five categories: serous, mucinous, endometrioid, clear-cell and Brenner. Mixed forms of tumor cells where there is a second or third cell type in addition to the main tumor cell are possible. 150 Nonepithelial tumors include: sex cord-stromal, germ-cell and indeterminate tumors. 148

Before proceeding with treatment, the extent of disease must be determined. Ovarian cancer is classified into four stages. Tumors are staged using the International Federation of Gynaecology (FIGO) system, which takes tumor grade, depth, width and extent of invasion into consideration (Table 19). 151 At the time of diagnosis approximately 75 percent of patients present with advanced disease. 149

Table 19 FIGO staging of ovarian cancer

Stage | Description
Stage I | Limited to ovaries
Ia | One ovary
Ib | Both ovaries
Ic | Ruptured capsule, surface tumor or positive washings
Stage II | Pelvic extension
IIa | Uterus, tube(s)
IIb | Other pelvic tissue
IIc | Positive washings, ascites
Stage III | Abdominal extension and/or regional lymph nodes
IIIa | Microscopic peritoneal metastases
IIIb | Macroscopic peritoneal metastases ≤ 2cm
IIIc | Macroscopic peritoneal metastases > 2 cm and/or regional lymph nodes
Stage IV | Distant metastases outside peritoneal cavity

Taken from Aebi et al.151

Two techniques are used in screening for ovarian cancer: serum tumor marker cancer antigen 125 (CA-125) and transvaginal ultrasonography (TVUS), neither of which seem to identify ovarian cancer at an early, potentially curable stage. Unlike cervical cancer, there has been no success in identifying precancerous lesions through screening techniques. The links between current epidemiological, biological and pathological data are not fully understood and there is a lack of animal models. Moreover, the disease is virulent and frequently diagnosed only in the advanced stages of disease. 149

Treatment for ovarian cancer typically involves surgery, the extent of which depends on the stage of disease. Total abdominal hysterectomy, bilateral salpingo-oophorectomy, omentectomy and peritoneal biopsies are required. Preserving fertility may be considered for younger patients with less advanced disease. For women with stage Ia or b, surgery alone should be adequate to treat the disease; however, patients with stage Ic or IIb may also require adjuvant chemotherapy. For more developed stages of disease, additional surgical goals include cytoreduction aiming at leaving no residual disease. Chemotherapy is also required and typically incorporates a platinum-based regime. 151 A second surgery to determine if further therapy in required may be performed. 144

### 5.2 Importance of Key Questions in the Clinical Management of Ovarian Cancer

The diagnostic work-up currently used for the characterization of ovarian lesions includes gynecological examination and TVUS. It has been reported that TVUS is not accurate enough to guarantee a precise differential diagnosis because benign and malignant ovarian lesions may present similar morphological characteristics. Measurement of specific serum tumor markers such as CA-125 is often used to detect recurrences; however, this does not allow localization of the recurrence or differentiation between local and diffused disease. Furthermore, nonrecurrent conditions like infections will often produce elevated CA-125 titers. Conventional imaging modalities such as MRI and helical CT with contrast enhancement are often used in conjunction with CA-125 to detect recurrences. However, detection of recurrences in small peritoneal lesions or differentiation of peritoneal abnormalities can be challenging. Early detection of recurrence in ovarian cancer may allow different therapeutic interventions that could improve outcomes and increase the chances of prolonged remission and survival. Additionally, ^18^FDG-PET may be capable of detecting early, small regions of relapse when other tests do not detect disease. 144 There is a need to evaluate the evidence on the use of ^18^FDG-PET in differentiating malignant from benign disease, staging and grading malignant disease, differentiating recurrent disease from therapy-induced changes and monitoring response to therapy in ovarian cancer.

### 5.3 Results

Twenty-four studies40,72-90,126-128,130 provided evidence on the use of ^18^FDG-PET or ^18^FDG-PET/CT for ovarian cancer. Twenty studies40,72-90 evaluated the diagnostic accuracy of ^18^FDG-PET or ^18^FDG-PET/CT, five studies75,89,126-128 reported on the diagnostic thinking impact of ^18^FDG-PET/CT, and one study130 evaluated the effects of ^18^FDG-PET as part of a management strategy on patient-centered outcomes. There were no economic evaluations on the use of ^18^FDG-PET or ^18^FDG-PET/CT for ovarian cancer. Characteristics of the populations, conditions of ^18^FDG-PET and ^18^FDG-PET/CT administration, interpretation of results and methodological quality of the studies are summarized in Appendices D to J.

#### 5.3.1 Diagnostic accuracy of ^18^FDG-PET and ^18^FDG-PET/CT in ovarian cancer

##### Characteristics of the studies

Twenty studies (fourteen prospective, 40,73-76,78,79,81,82,84,85,87,88,90 six retrospective72,77,80,83,86,89) evaluated the diagnostic accuracy of ^18^FDG-PET40,77,79,81,84,88,90 or ^18^FDG-PET/CT. 74 Twelve studies used ^18^FDG-PET to assess recurrences, 72,73,75,77,78,80-83,86,88,89 two for primary diagnosis, 79,85 two for initial staging, 76,90 two for restaging purposes, 84,87 one for primary diagnosis and initial staging, 74 and one for initial staging and assessing recurrences. The studies contained a total of 871 patients with sample sizes ranging from 13 to 101 participants. The participants ages ranged in age from 17 to 89 years. ^18^FDG-PET was compared to a reference standard that varied across the studies. In ten studies the reference standard was exclusively histology/biopsy, 72-74,76,79,83-85,87,90 in nine studies it was either histology/biopsy or clinical followup, 75,77,78,80-82,86,88,89 and in one study the reference standard was histology/biopsy or conventional imaging. 40 Seven studies reported the mean time between last treatment and ^18^FDG-PET as 6 months or more, 72,73 less than 6 months, 77 3 months or more, 83 3.6 months, 80 30 days84 and 29 days. 87 Six studies used a fixed dose of ^18^FDG-PET of 350 MBq78 or 370 MBq, 79,81,82,87,90 five studies used a weight-based dose of 6.5 MBq/kg, 76 5.5 MBq/kg, 74 5.2 MBq/kg, 84 or 0.22 mCi/kg; 75,83 six studies reported doses ranging from 260 to 666 MBq. 40,77,80,85,86,89 When reported, the time between injection and PET scan ranged from 45 to 90 minutes. Patients fasted for four hours, 40,72,73,75,83 six hour, 74,76,77,80-82,84-89 or twelve hours; 79,90 one study78 did not indicate fasting. Thirteen studies72,73,75,77,78,80-84,86,87,89 measured glucose levels before administration of ^18^FDG-PET; the maximum glucose levels allowed were normal levels, 78,80,82 200 mg/dL, 72,73,83,86,89 140 mg/dL, 81,87 and 7.5 mmol/L. 77 Methods of interpretation of the images were qualitative in nine studies72,73,77,80,81,85-87,89 and both qualitative and quantitative in seven studies. 74,75,78,79,82,84,90 Scans were interpreted qualitatively using visual analysis in all studies. SUV values were reported in five studies for the interpretation of the PET images. The criterion for abnormality was SUV greater than 3 g/mL74,75,87,88 or greater than 2.5 g/mL. 78

##### Comparisons

Comparisons for which data were considered for meta-analysis are summarized in Table 20. Pooled data were obtained to evaluate the accuracy of ^18^FDG-PET and ^18^FDG-PET/CT for assessing recurrences of ovarian cancer. Individual study data are summarized in Appendix D.

Table 20 Summary of comparisons considered for meta-analyses of the accuracy of ^18^FDG-PET and ^18^FDG-PET/CT for ovarian cancer

Indication | Studies | Design | Type of PET | Reference standard | Meta-analysis
Primary diagnosis and staging | Castellucci 2007^74^ | P | FDG-PET/CT | Histology/biopsy | No
Staging and recurrences | Grisaru 2004^40^ | P | FDG-PET | Histology/biopsy or clinical followup | No
Primary diagnosis | Kawahara 2004^79^ | P | FDG-PET | Histology/biopsy | No
Primary diagnosis | Risum 2007^85^ | P | FDG-PET/CT | Histology/biopsy | No
Recurrences | Bristow 2003^73^ | P | FDG-PET/CT | Histology/biopsy | 1. FDG-PET v. histology/biopsy or clinical followup (P studies) 81,88 2. FDG-PET/CT v. any reference standard (P studies) 73,75,78,82 3. FDG-PET/CT v. histology/biopsy or clinical followup (P studies) 75,78,82 4. FDG-PET/CT v. any reference standard (R studies) 72,80,83,86,89 5. FDG-PET/CT v. histology/biopsy or clinical followup (R studies) 80,86,89 6. FDG-PET/CT v. histology/biopsy (R studies) 72,83
Recurrences | Bristow 2005^72^ | R | FDG-PET/CT | Histology/biopsy
Recurrences | Chung 2007^75^ | P | FDG-PET/CT | Histology/biopsy or clinical followup
Recurrences | Garcia-Velloso 2007^77^ | R | FDG-PET | Histology/biopsy or clinical followup
Recurrences | Hauth 2005^78^ | P | FDG-PET/CT | Histology/biopsy or clinical followup
Recurrences | Kim 2007^80^ | R | FDG-PET/CT | Histology/biopsy or clinical followup
Recurrences | Murakami 2006^81^ | P | FDG-PET | Histology/biopsy or clinical followup
Recurrences | Nanni 2005^82^ | P | FDG-PET/CT | Histology/biopsy or clinical followup
Recurrences | Pannu 2004^83^ | R | FDG-PET/CT | Histology/biopsy
Recurrences | Sebastian 2008^86^ | R | FDG-PET/CT | Histology/biopsy or clinical followup
Recurrences | Takekuma 2005^88^ | P | FDG-PET | Histology/biopsy or clinical followup
Recurrences | Thrall 2007^89^ | R | FDG-PET/CT | Histology/biopsy or clinical followup
Restaging | Picchio 2003^84^ | P | FDG-PET | Histology/biopsy | No
Restaging | Sironi 2004^87^ | P | FDG-PET/CT | Histology/biopsy | No
Staging | Drieskens 2003^76^ | P | FDG-PET/CT | Histology/biopsy | No
Staging | Yoshida 2004^90^ | P | FDG-PET | Histology/biopsy | No

CT = computed tomography; FDG = fluorodeoxyglucose F18; P = prospective; PET = positron emission tomography; R = retrospective

###### 1 ^18^FDG-PET for recurrences of ovarian cancer

Reference standard: histology/biopsy or clinical followup; prospective studies. Two prospective studies81,88 totaling 119 participants provided data for a meta-analysis of the accuracy of ^18^FDG-PET v. histology/biopsy or clinical followup to detect recurrences of ovarian cancer. Individual 2x2 table results are presented in Figure 43. Sensitivities were 91 percent81 and 85 percent; 88 specificity was 100 percent.

Figure 43 Results from 2x2 tables of individual prospective studies of ^18^FDG-PET v. histology/biopsy or clinical followup to detect recurrences of ovarian cancer

We found that ^18^FDG-PET had a pooled positive LR of 22.4 (95% CI = 1.64, 305.38) and a pooled negative LR of 0.13 (95% CI = 0.06, 0.29) to accurately detect recurrences of ovarian cancer (Figures 44 and 45). Both the positive and negative LRs were statistically significant and therefore, ^18^FDG-PET seems to be helpful for identifying recurrences of the disease. There was moderate heterogeneity in the positive LR (p = 0.17; I^2^ = 47 percent); negative LR was homogeneous across studies.

Figure 44 Meta-analysis of the positive likelihood ratio of ^18^FDG-PET v. histology/biopsy or clinical followup to detect recurrences of ovarian cancer (prospective studies)

Figure 44 is a meta-graph depicting the positive likelihood ratio of 18FDG-PET versus histology/biopsy or clinical followup for detecting recurrences of ovarian cancer. This figure is discussed in Chapter 5 (page 89). Two prospective studies contributed 119 participants. It was found that 18FDG-PET had a pooled positive likelihood ratio of 22.4 (95 percent confidence interval 1.64, 305.38) to accurately detect recurrences of ovarian cancer. This ratio was statistically significant. There was moderate heterogeneity in the positive likelihood ratio (p=0.17, I2 = 47) across the studies.

Figure 45 Meta-analysis of the negative likelihood ratio of ^18^FDG-PET v. histology/biopsy or clinical followup to detect recurrences of ovarian cancer (prospective studies)

Figure 45 is a meta-graph depicting the negative likelihood ratio of 18FDG-PET versus histology/biopsy or clinical followup for detecting recurrences of ovarian cancer. This figure is discussed in Chapter 5 (page 89). Two prospective studies contributed 119 participants. It was found that 18FDG-PET had a pooled negative likelihood ratio of 0.13 (95 percent confidence interval 0.06, 0.29) to accurately detect the recurrences of ovarian cancer. This ratio was statistically significant.

Figure 46 shows the estimates of sensitivity and 1-specificity plotted in ROC space for ^18^FDG-PET v. histology/biopsy or clinical followup to detect recurrences of ovarian cancer based on prospective studies.

Figure 46 Summary ROC plot of ^18^FDG-PET v. histology/biopsy or clinical followup to detect recurrences of ovarian cancer (prospective studies)

Figure 46 is summary receiver operating characteristics plot of 18FDG-PET versus histology/biopsy or clinical followup to detect recurrences of ovarian cancer (prospective studies). The figure shows the estimates of sensitivity and 1-specificity both included studies. Specificity is recorded along the X-axis and sensitivity is recorded along the Y-axis. The curve appears near the upper left hand corner (page 90).

###### 2 ^18^FDG-PET/CT for recurrences of ovarian cancer

Reference standard: any; prospective studies. Four prospective studies73,75,78,82 totaling 159 participants provided data for a meta-analysis of the accuracy of ^18^FDG-PET/CT v. any reference standard to detect recurrences of ovarian cancer. Individual 2x2 table results are presented in Figure 47. Sensitivity ranged from 83 percent73 to 100 percent. 78 Specificity ranged from 71 percent82 to 100 percent. 78

Figure 47 Results from 2x2 tables of individual prospective studies of ^18^FDG-PET/CT v. any reference standard to detect recurrences of ovarian cancer

We found that ^18^FDG-PET/CT had a pooled positive LR of 6.97 (95% CI = 1.64, 25) and a pooled negative LR of 0.12 (95% CI = 0.06, 0.26) to accurately detect recurrences of ovarian cancer (Figures 48 and 49). Both the positive and negative LRs were statistically significant and therefore, ^18^FDG-PET/CT seems to be helpful for identifying recurrences of the disease. There was moderate heterogeneity in the positive LR (p = 0.10; I^2^ = 52 percent); negative LR was homogeneous across studies.

Figure 48 Meta-analysis of the positive likelihood ratio of ^18^FDG-PET/CT v. any reference standard to detect recurrences of ovarian cancer (prospective studies)

Figure 48 is a meta-graph depicting the positive likelihood ratio of 18FDG-PET/CT versus any reference standard for detecting recurrence of ovarian cancer. This figure is discussed in Chapter 5 (page 91). Four prospective studies contributed data from 159 participants. The pooled positive likelihood ratio to rule in recurrence of ovarian cancer was 6.97 (95% confidence interval 1.64, 25). This ratio was statistically significant. There was moderate heterogeneity in the positive likelihood ratio (p = 0.10, I2 = 52 percent) across the studies.

Figure 49 Meta-analysis of the negative likelihood ratio of ^18^FDG-PET/CT v. any reference standard to detect recurrences of ovarian cancer (prospective studies)

Figure 49 is a meta-graph depicting the negative likelihood ratio of 18FDG-PET/CT versus any reference standard for detecting recurrence of ovarian cancer. This figure is discussed in Chapter 5 (page 91). Four prospective studies contributed data from 159 participants. The pooled negative ratio to rule out recurrence of ovarian cancer was 0.12 (95% confidence interval 0.06, 0.26). The negative likelihood ratio was statistically significant.

Figure 50 shows the estimates of sensitivity and 1-specificity plotted in ROC space for ^18^FDG-PET/CT v. any reference standard to detect recurrences of ovarian cancer based on prospective studies.

Figure 50 Summary ROC plot of ^18^FDG-PET/CT v. any reference standard to detect recurrences of ovarian cancer (prospective studies)

Figure 50 is a summary receiver operating characteristics plot of 18FDG-PET/CT versus any reference standard to detect recurrences of ovarian cancer. The figure shows the paired estimates of sensitivity and 1-specificity for the four included studies. Specificity is recorded along the X-axis and sensitivity is recorded along the Y-axis. The curve appears near the top of the left hand corner (page 92).

Reference standard: histology/biopsy or clinical followup, prospective studies (subgroup analysis). Three prospective studies75,78,82 totaling 137 participants provided data for a subgroup analysis of the diagnostic accuracy of ^18^FDG-PET/CT when histology/biopsy or clinical followup were used as the reference standard to detect recurrences of ovarian cancer. Individual 2x2 table results are presented in Figure 51. Sensitivity ranged from 88 percent82 to 100 percent. 78 Specificity ranged from 71 percent82 to 100 percent. 78

Figure 51 Results from 2x2 tables of individual prospective studies of ^18^FDG-PET/CT v. histology/biopsy or clinical followup for detecting recurrences of ovarian cancer (subgroup analysis)

We found that when only histology/biopsy were considered as reference standard, ^18^FDG-PET/CT had a pooled positive LR of 9.84 (95% CI = 1.64, 59.15) and a pooled negative LR of 0.10 (95% CI = 0.05, 0.22) to accurately detect recurrences of ovarian cancer (Figures 52 and 53). Both the positive and negative LRs were statistically significant and therefore, ^18^FDG-PET/CT seems to be helpful for identifying recurrences of the disease. The positive LR was moderately heterogeneous (p = 0.06, I^2^ = 64 percent); the negative LR was homogeneous across the studies.

Figure 52 Meta-analysis of the positive likelihood ratio of ^18^FDG-PET/CT v. histology/biopsy or clinical followup for detecting recurrences of ovarian cancer (prospective studies)

Figure 52 is a meta-graph depicting the positive likelihood ratio of 18FDG-PET/CT versus histology/biopsy of clinical followup for detecting recurrences of ovarian cancer. This figure is described in Chapter 5 (page 93). Three prospective studies contributed data from 137 participants. The pooled positive likelihood ratio to rule in recurrence of ovarian cancer was 9.84 (95% confidence interval 1.64, 59.15). This ratio was statistically significant. Moderate heterogeneity (p=0.06, I2 = 64 percent) was present.

Figure 53 Meta-analysis of the negative likelihood ratio of ^18^FDG-PET/CT v. histology/biopsy or clinical followup for detecting recurrences of ovarian cancer (prospective studies)

Figure 53 is a meta-graph depicting the negative likelihood ratio of 18FDG-PET/CT versus histology/biopsy of clinical followup for detecting recurrences of ovarian cancer. This figure is described in Chapter 5 (page 93). Three prospective studies contributed data from 137 participants. The pooled negative likelihood ratio to rule out recurrence of ovarian cancer was 0.10 (95% confidence interval 0.05, 0.22). This ratio was statistically significant. The negative likelihood ratio was homogenous across the studies.

Figure 54 shows the estimates of sensitivity and 1-specificity plotted in ROC space for ^18^FDG-PET/CT v. histology/biopsy or clinical followup to detect recurrences of ovarian cancer based on prospective studies.

Figure 54 Summary ROC plot of ^18^FDG-PET v. histology/biopsy or clinical followup to detect recurrences of ovarian cancer (prospective studies)

Figure 54 is a summary receiver operating characteristics plot of 18FDG-PET/CT versus histology/biopsy or clinical followup to detect recurrences of ovarian cancer. The figure shows the paired estimates of sensitivity and 1-specificityfor the three included prospective studies. Specificity is recorded on the X-axis and sensitivity is recorded along the Y-axis. The curve appears near the top left hand corner (page 93).

Reference standard: any; retrospective studies. Separate meta-analyses were conducted for retrospective studies. Five retrospective studies72,80,83,86,89 totaling 180 participants provided data for a meta-analysis of the accuracy of ^18^FDG-PET/CT v. any reference standard to detect recurrences of ovarian cancer. Individual 2x2 table results are presented in Figure 55. Sensitivity ranged from 73 percent80,83 to 97 percent. 86 Specificity ranged from 40 percent83 to 100 percent. 72,89

Figure 55 Results from 2x2 tables of individual retrospective studies of ^18^FDG-PET/CT v. any reference standard to detect recurrences of ovarian cancer to accurately detect recurrences of ovarian cancer

Based on the analysis of retrospective studies, we found that ^18^FDG-PET/CT had a pooled positive LR of 6.02 (95% CI = 1.40, 25.91) and a pooled negative LR of 0.19 (95% CI = 0.08, 0.45) to accurately detect recurrences of ovarian cancer (Figures 56 and 57). The positive and negative LRs were statistically significant and therefore, ^18^FDG-PET/CT seems to be helpful for identifying recurrences of the disease. However, both the positive (p = 0.001; I^2^ = 78 percent) and the negative (p = 0.02; I^2^ = 66 percent) LRs were heterogeneous across the studies precluding firm conclusions based on these results.

Figure 56 Meta-analysis of the positive likelihood ratio of ^18^FDG-PET/CT v. any reference standard to detect recurrences of ovarian cancer (retrospective studies)

Figure 56 is a meta-graph depicting the positive likelihood ratio of 18FDG-PET/CT versus any reference standard to detect recurrences of ovarian cancer. The figure is discussed in Chapter 5 (page 94-95). Five retrospective studies contributed data from 180 participants. The pooled positive likelihood ratio to rule in the recurrence of ovarian cancer was 6.02 (95% confidence interval 1.40, 25.91). This ratio was statistically significant. Considerable heterogeneity (p = 0.001, I2 = 78 percent) was present.

Figure 57 Meta-analysis of the negative likelihood ratio of ^18^FDG-PET/CT v. any reference standard to detect recurrences of ovarian cancer (retrospective studies)

Figure 57 depicts the negative likelihood ratio of 18FDG-PET/CT versus any reference standard to detect recurrences of ovarian cancer. The figure is discussed in Chapter 5 (page 94-95). Five retrospective studies contributed data from 180 participants. The pooled negative likelihood ratio to rule out the recurrence of ovarian cancer was 0.19 (95% confidence interval 0.08, 0.45). This ratio was statistically significant. Considerable heterogeneity (p = 0.02, I2 = 66 percent) was present.

Figure 58 shows the estimates of sensitivity and 1-specificity plotted in ROC space for ^18^FDG-PET/CT v. any reference standard to detect recurrences of ovarian cancer based on retrospective studies.

Figure 58 Summary ROC plot of ^18^FDG-PET v. any reference standard to detect recurrences of ovarian cancer (retrospective studies)

Figure 58 is a summary receiver operating characteristics plot of 18FDG-PET versus any reference standard to detect recurrences of ovarian cancer. The figure shows the paired estimates of sensitivity and 1-specificity for the five included retrospective studies. Specificity is recorded along the X-axis and sensitivity is recorded along the Y-axis. The curve appears near the top left hand corner (page 95).

Reference standard: histology/biopsy or clinical followup, retrospective studies (subgroup analysis). Three retrospective studies80,86,89 totaling 140 participants provided data for a subgroup analysis of the diagnostic accuracy of ^18^FDG-PET/CT when histology/biopsy or clinical followup were used as the reference standard to detect recurrences of ovarian cancer. Individual 2x2 table results are presented in Figure 59. Sensitivity ranged from 73 percent80 to 97 percent. 86 Specificity ranged from 80 percent86 to 100 percent. 89

Figure 59 Results from 2x2 tables of individual retrospective studies of ^18^FDG-PET/CT v. histology/biopsy or clinical followup to detect recurrences of ovarian cancer (subgroup analysis)

We found that when only histology/biopsy or clinical followup were considered as reference standard in retrospective studies, ^18^FDG-PET/CT had a pooled positive LR of 6.68 (95% CI = 2.86, 15.64) and a pooled negative LR of 0.10 (95% CI = 0.02, 0.44) to accurately detect recurrences of ovarian cancer (Figures 60 and 61). The positive and negative LRs were statistically significant and therefore, ^18^FDG-PET/CT seems to be helpful for identifying recurrences of the disease. The positive LR was homogeneous across the studies; however, the negative LR was heterogeneous across the studies (p = 0.01; I^2^ = 77 percent).

Figure 60 Meta-analysis of the positive likelihood ratio of ^18^FDG-PET/CT v. histology/biopsy or clinical followup to detect recurrences of ovarian cancer (retrospective studies)

Figure 60 is a meta-graph that depicts the positive likelihood ratio of 18FDG-PET/CT versus histology/biopsy or clinical followup to detect recurrences of ovarian cancer. The figure is discussed in Chapter 5 (page 97). Three retrospective studies contributed to data from 140 participants. The pooled positive likelihood ratio to rule in recurrence of ovarian cancer was 6.68 (95% confidence interval 2.86, 15.64). This ratio was statistically significant. The positive likelihood ratio was homogeneous across the studies.

Figure 61 Meta-analysis of the negative likelihood ratio of ^18^FDG-PET/CT v. histology/biopsy or clinical followup to detect recurrences of ovarian cancer (retrospective studies)

Figure 61 is a meta-graph that depicts the negative likelihood ratio of 18FDG-PET/CT versus histology/biopsy or clinical followup to detect recurrences of ovarian cancer. The figure is discussed in Chapter 5 (page 97). Three retrospective studies contributed data from 140 participants. The pooled negative likelihood ratio to rule out recurrence of ovarian cancer was 0.10 (95% confidence interval 0.02, 0.44). This ratio was statistically significant. Considerable heterogeneity (p = 0.01, I2 = 77 percent) was present.

Figure 62 shows the estimates of sensitivity and 1-specificity plotted in ROC space for ^18^FDG-PET/CT v. histology/biopsy or clinical followup to detect recurrences of ovarian cancer based on retrospective studies.

Figure 62 Summary ROC plot of ^18^FDG-PET v. histology/biopsy or clinical followup to detect recurrences of ovarian cancer (retrospective studies)

Figure 62 is summary receiver operating characteristics plot of 18FDG-PET versus histology/biopsy or clinical followup to detect recurrences of ovarian cancer. The figure shows the paired estimates of sensitivity and 1-specificity for the three included retrospective studies. Specificity is recorded along the X-axis and sensitivity recorded along the Y-axis. The curve appears near the top of the left hand corner (page 98).

Reference standard: histology/biopsy, retrospective studies (subgroup analysis). Two retrospective studies72,83 totaling 40 participants provided data for a subgroup analysis of the diagnostic accuracy of ^18^FDG-PET/CT when only histology/biopsy was used as the reference standard to detect recurrences of ovarian cancer. Individual 2x2 table results are presented in Figure 63. Sensitivities were 73 percent83 and 77 percent; 72 specificities were 40 percent83 and 100 percent. 72

Figure 63 Results from 2x2 tables of individual retrospective studies of ^18^FDG-PET/CT v. histology/biopsy or clinical followup to detect recurrences of ovarian cancer (subgroup analysis)

We found that when only histology/biopsy was considered as the reference standard in retrospective studies, ^18^FDG-PET/CT had a pooled positive LR of 3.97 (95% CI = 0.09, 167.47) and a pooled negative LR of 0.36 (95% CI = 0.15, 0.86) to accurately detect recurrences of the disease (Figures 64 and 65). The positive LR was not statistically significant and was heterogeneous across the studies (p = 0.008; I^2^ = 86 percent), precluding any reliable interpretation from the results.

Figure 64 Meta-analysis of the positive likelihood ratio of ^18^FDG-PET/CT v. histology/biopsy to detect recurrences of ovarian cancer (retrospective studies)

Figure 64 is a meta-graph depicting the positive likelihood ratio of 18FDG-PET/CT versus histology/biopsy to detect recurrences of ovarian cancer. The figure is discussed in chapter 5 (page 99). Two retrospective studies contributed data from 40 participants. The pooled positive likelihood ratio to rule in recurrence of ovarian cancer was 3.97 (95% confidence interval 0.09, 167.47). This ratio was not statistically significant. Considerable heterogeneity was (p = 0.008, I2 = 86 percent).

Figure 65 Meta-analysis of the negative likelihood ratio of ^18^FDG-PET/CT v. histology/biopsy to detect recurrences of ovarian cancer (retrospective studies)

Figure 65 is a meta-graph analysis of the negative likelihood ratio of 18FDG-PET/CT versus histology/biopsy to detect recurrences of ovarian cancer. The figure is discussed in chapter 5 (page 99). Two retrospective studies contribute data from 40 participants. The pooled negative likelihood ratio to rule in recurrence of ovarian cancer was 0.36 (95% confidence interval 0.15, 0.86). This ratio was statistically significant.

Figure 66 shows the estimates of sensitivity and 1-specificity plotted in ROC space for ^18^FDG-PET/CT v. histology/biopsy to detect recurrences of ovarian cancer based on retrospective studies.

Figure 66 Summary ROC plot of ^18^FDG-PET v. histology/biopsy to detect recurrences of ovarian cancer (retrospective studies)

Figure 66 is a summary receiver operating characteristics plot of 18FDG-PET/CT versus histology/biopsy to detect recurrences of ovarian cancer. The figure shows the paired estimates of sensitivity and 1-specificity for both of the included studies. Specificity is recorded along the X-axis and sensitivity is recorded along the Y-axis. The curve appears near the top left hand corner (page 99).

##### Summary of the results

Meta-analyses were calculated to evaluate the accuracy of ^18^FDG-PET and ^18^FDG-PET/CT in detecting recurrences of ovarian cancer (Table 21). Pooled positive and negative LRs showed a consistent, statistically significant effect across a range of reference standards and study designs, providing evidence in support of the usefulness of ^18^FDG-PET and ^18^FDG-PET/CT in detecting recurrences. Only one comparison did not yield a statistically significant positive LR, however this result could be attributed to smaller numbers of studies in the analysis and smaller samples (i.e. n=40 v. n>100 in other comparisons).

Table 21 Results of meta-analyses of the accuracy of ^18^FDG-PET and ^18^FDG-PET/CT for ovarian cancer

PET Purpose | Type of PET | Reference standard | Design | Studies | N | Effect estimate M-H, Random, 95% CI
Recurrences | FDG-PET | Histology/biopsy or clinical followup | P | 2 | 119 | PLR = 22.40 [1.64, 305.38]
Recurrences | FDG-PET | Histology/biopsy or clinical followup | P | 2 | 119 | NLR = 0.13 [0.06, 0.29]
Recurrences | FDG-PET/CT | Any reference standard | P | 4 | 159 | PLR = 6.97 [1.94, 25.00]
Recurrences | FDG-PET/CT | Any reference standard | P | 4 | 159 | NLR = 0.12 [0.06, 0.26]
Recurrences | FDG-PET/CT | Histology/biopsy or clinical followup | P | 3 | 137 | PLR = 9.84 [1.64, 59.15]
Recurrences | FDG-PET/CT | Histology/biopsy or clinical followup | P | 3 | 137 | NLR = 0.10 [0.05, 0.22]
Recurrences | FDG-PET/CT | Any reference standard | R | 5 | 180 | PLR = 6.02 [1.40, 25.91]
Recurrences | FDG-PET/CT | Any reference standard | R | 5 | 180 | NLR = 0.19 [0.08, 0.45]
Recurrences | FDG-PET/CT | Histology/biopsy or clinical followup | R | 3 | 140 | PLR = 6.68 [2.86, 15.64]
Recurrences | FDG-PET/CT | Histology/biopsy or clinical followup | R | 3 | 140 | NLR = 0.10 [0.02, 0.44]
Recurrences | FDG-PET/CT | Histology/biopsy | R | 2 | 40 | PLR = 3.97 [0.09, 167.47]
Recurrences | FDG-PET/CT | Histology/biopsy | R | 2 | 40 | NLR = 0.36 [0.15, 0.86]

CI = confidence interval; FDG= fluorodeoxyglucose F18; M-H = Mantel Hantzel; NLR=negative likelihood ratio; P=prospective; PET=positron emission tomography; PLR=positive likelihood ratio; R=retrospective

#### 5.3.2 Diagnostic thinking impact of ^18^FDG-PET and ^18^FDG-PET/CT on physician decision making with respect to diagnosis and management strategy for patients with ovarian cancer

All five studies75,89,126-128 considered integrated ^18^FDG-PET/CT imaging to assess for ovarian cancer recurrence. None of the studies evaluated the diagnostic thinking impact of ^18^FDG-PET alone. The included studies assessed the impact of ^18^FDG-PET/CT imaging on the management of patients suspected of suffering a recurrence of cancer as well as for surveillance of recurrences in patients following treatment for their primary cancer.

Chung et al. 75 evaluated the accuracy of ^18^FDG-PET/CT imaging on diagnosis of suspected recurrences of ovarian cancer and whether the results altered either treatment decisions or additional diagnostic testing regimes for the participants. This prospective study enrolled 77 women with suspected cancer recurrence. ^18^FDG-PET/CT impacted either the diagnostic followup or the treatment plan in 19 cases (25 percent). The majority of changes (11/19) occurred in cases with a positive ^18^FDG-PET/CT scan and no other clinical indicators of tumor recurrence. These 11 patients had normal CA-125 and no clinical symptoms. The treatment plan was changed from observation to a regime of chemotherapy. Eight patients whose CA-125 levels were elevated were shown to have only physiological or inflammatory ^18^FDG uptake. The need for additional diagnostic procedures was eliminated and the patients were followed by normal observation. Overall, ^18^FDG-PET/CT was determined to have high impact on patient care.

The authors concluded that ^18^FDG-PET/CT was a sensitive surveillance method to identify cervical cancer recurrences and that it allowed for the optimization and customization of an appropriate treatment plan.

This prospective study was assessed as being of moderate quality. The spectrum of patients that were included and the details of the selection criteria, as well as the choice and administration of the reference standard were well described. There was also a good description of the ^18^FDG-PET/CT procedure and intermediate test results. Reporting was inadequate on some aspects, notably the time delay between the ^18^FDG-PET/CT scan and the reference verification of disease status, the lack of detail of the reference test procedure, and the unblinded interpretation of the final reference standard. Additionally, because the disease status of patients was not verified by one reference standard, there is the possibility of verification bias.

Mangili et al. 126 evaluated the impact of ^18^FDG-PET/CT imaging on the management decisions for patients suspected to have ovarian cancer recurrence. Data from a chart review of 32 patients who underwent ^18^FDG-PET/CT scans were used in this study. All patients had previously undergone surgery and chemotherapy for ovarian cancer. The suspicion of recurrence was based on a number of followup measures, including elevated serum CA-125 or abnormalities on an annual chest X-ray or abdominal ultrasound. The impact on patient management was assessed retrospectively in a blinded fashion. All pertinent information (e.g., diagnosis, staging, previous treatment of primary tumor, followup including CA-125 values and imaging studies, and the detailed CT report) from the patient charts was collected and distributed to two teams of oncologists. Each team completed a pre-test questionnaire regarding clinical management. Where there was a discrepancy between the care plans, the teams were asked to reach consensus regarding patient management. The ^18^FDG-PET/CT scans were then distributed with the coded patient information and in a different sequence than the pre-test charts. Both teams came to a post-test consensus on the most appropriate course of clinical management. The addition of ^18^FDG-PET/CT images to the patient information resulted in changes to the treatment plans for 14 patients (44 percent). The treatment modality was altered for eight patients, including receiving chemotherapy rather than surgery or vice versa (n = 4), undergoing further examination (e.g., CT) rather than diagnostic surgery (n = 1), or chemotherapy rather than diagnostic surgery (n = 3). Prior to ^18^FDG-PET/CT, seven patients were designated to the observation approach; however, with the addition of ^18^FDG-PET/CT, this decision was changed for six patients. Of these, two underwent further diagnostic procedures, while four underwent changes to their treatment plans to undergo chemotherapy (n = 1) or surgery (n = 3). Thus, for seven patients (22 percent), the ^18^FDG-PET/CT imaging facilitated a change in management from either further invasive diagnostics or a “watch and see” approach to a definitive treatment plan. There was an increase in the overall number of patients undergoing chemotherapy (10/32 to 16/32) as a result of the discovery of more disseminated disease based on the ^18^FDG-PET/CT images.

The authors concluded that ^18^FDG-PET/CT imaging for detection of ovarian cancer recurrence demonstrated a higher level of accuracy compared to conventional contrast enhanced CT. The authors suggested that use of integrated ^18^FDG-PET/CT with a fully diagnostic CT could replace the current approach of using multiple imaging modalities from a number of sessions to restage ovarian cancer recurrences.

This retrospective chart review was determined to be of moderate quality. The spectrum of included patients, choice and administration of the reference standard and the inclusion of intermediate test results were well reported. Additionally, all cases were verified by a reference standard that was interpreted without knowledge of the ^18^FDG-PET/CT results. Descriptions provided for withdrawals were satisfactory. There was inadequate reporting on some aspects, including the inclusion criteria, the blinded interpretation of the ^18^FDG-PET/CT imaging, and the period of time between the administration of the ^18^FDG-PET/CT scan and the reference standard. There was more than one reference standard test used to verify disease status, which may have introduced verification bias.

Simcock et al. 127 investigated the treatment decision impact of integrated ^18^FDG-PET/CT imaging on the restaging and management of recurrent ovarian cancer in a population of 61 patients. Of these, 56 had sufficient followup data to be included in the analysis (median total followup: 21.6 months). Collectively, these patients underwent 66 ^18^FDG-PET/CT scans; the majority of women (86 percent) had one scan.

The disease state immediately prior to each of the 66 ^18^FDG-PET/CT scans were described as follows: “uncertain” (n = 30), “suspected local recurrence” (n = 15), “suspected systemic disease” (n = 14), and “surveillance with no evidence of disease” (n = 7). The impact of the ^18^FDG-PET/CT imaging on the patient management plans was “high” for 32 patients (57 percent) who received a total of 33 ^18^FDG-PET/CT scans. Twenty-nine scans had a low impact on patient management. Of the 32 high-impact management changes, 20 occurred in patients who were not assigned a disease state using conventional assessment. As there were 30 patients in this “uncertain” category following their conventional staging, two-thirds of the patients were diagnosed following the ^18^FDG-PET/CT. The ^18^FDG-PET/CT facilitated changes ranging from altering an active treatment approach to observation (n = 6), or from observation to treatment by radiation, chemotherapy or surgery (n = 7). Thus, in 13 patients (23 percent) the results of the ^18^FDG-PET/CT determined whether or not they received treatment. Other high-impact modality changes included switching from surgery to chemotherapy (n = 6), chemotherapy to radiation or a combination of therapies (n = 4), biopsy to chemotherapy or surgery (n = 4), radiation to chemotherapy or enlargement of radiation target fields (n = 1), and switching from a combination of therapies to radiation or chemotherapy alone (n = 2).

Additionally, prognostic outcomes were reported. The survival of patients was analyzed according to their ^18^FDG-PET/CT determined disease status (systemic, localized, or no disease/equivocal). While there was no significant difference in overall survival among the three groups, there was significantly lower survival in patients with ^18^FDG-PET/CT designated systemic disease v. the combined ^18^FDG-PET/CT designated localized and no disease/equivocal patient survival.

The authors concluded that the use of ^18^FDG-PET/CT in monitoring patients with recurrent or suspected recurrent ovarian cancer significantly modified the assessment of the cancer state. They also concluded that ^18^FDG-PET/CT altered management in a substantial proportion of patients.

This prospective study was determined to be of moderate quality. The selection criteria, choice and execution of the reference standard, and intermediate test results were well reported. Additionally, all cases were verified by a reference standard, and there was satisfactory explanation for withdrawals. However, reporting was inadequate on some aspects, notably of whether or not the spectrum of patients was representative of typical clinical practice, which raises the possibility of selection bias. In addition, the lack of blinded interpretation of either the ^18^FDG-PET/CT scans or the reference standards may have introduced review bias to the interpretation of results. Furthermore, the period of time between the administration of the ^18^FDG-PET/CT scan and the reference standard was unclear, and there was no standard reference test; rather, a combination of methods was used (histological or clinical followup). This variation in validation of the diagnosis may have lead to verification bias

Soussan et al. 128 investigated the impact of ^18^FDG-PET/CT on treatment decision for the management of possible recurrent ovarian cancer. This prospective study enrolled 29 outpatients who underwent ^18^FDG-PET/CT scans. All patients had previously undergone surgery and chemotherapy. Two questionnaires were completed by the treating oncologists to determine the impact of ^18^FDG-PET/CT on management decisions; the first was completed following the independent CT scan but prior to the ^18^FDG-PET/CT scan, and the second was completed upon receipt of the ^18^FDG-PET/CT data. Followup data were also collected from the referring oncologists.

The final therapeutic decision was changed based on the results of the ^18^FDG-PET/CT for 10 patients (34 percent). The modality of therapy for the patient changed in three cases (e.g., chemotherapy to chemotherapy plus surgery); for six patients there was a change in plan from an approach of observation to treatment. One patient was switched from chemotherapy to observation. There was major modification in the assessment of disease distribution in 15 patients (52 percent); of these, 11 had more advanced disease and four had more limited disease. A minor change in distribution was found in one patient. Of these patients, nine had their treatment plan altered as a result.

The authors concluded that the use of ^18^FDG-PET/CT in evaluating patients with suspicion of recurrent ovarian cancer significantly modified treatment decisions. The impact was particularly important for the management of cases that were determined to be positive by ^18^FDG-PET/CT despite being assessed as negative by CT alone.

This prospective study was determined to be of high quality. The choice and execution of the reference standard, description of the ^18^FDG-PET/CT interpretation, and inclusion of intermediate test results were well reported. Additionally, all cases were verified by a reference standard, and all enrolled participants were accounted for satisfactorily. However, there was inadequate reporting on some aspects, including whether or not the spectrum of patients was representative of typical clinical practice. The reference standard used to verify disease included a number of measures, which varied among patients, thus leading to potential verification bias. It was unclear whether the interpretation of either the ^18^FDG-PET/CT or the reference standard was blinded.

Thrall et al. 89 retrospectively investigated the treatment decision impact for 39 patients who underwent integrated ^18^FDG-PET/CT scans. All patients had confirmed ovarian cancer; the majority (69 percent) assessed to have stage III. All patients had undergone cytoreductive surgery and platinum-based chemotherapy. The analysis of possible recurrences included a total of 59 ^18^FDG-PET/CT scans. Indications for undergoing ^18^FDG-PET/CT imaging ranged from a routine component with no clinical or imaging abnormalities (n = 4 scans) to abnormalities such as elevated serum CA-125 (n = 24), clinical symptoms of recurrence (n = 9), abnormal CT scan (n = 14), and assessment of treatment response (n = 8). Twenty-five patients had one ^18^FDG-PET/CT scan, 10 patients had two ^18^FDG-PET/CT scans, two patients had either three or four scans.

During the followup period, 33 patients (85 percent) had a cancer recurrence. Of 24 ^18^FDG-PET/CT scans performed in 22 patients, 18 scans correctly identified recurrences (75 percent). The correct determination of recurrence was associated with subsequent clinical management decisions. Overall, ^18^FDG-PET/CT imaging resulted in changes to the treatment plans of 14 patients (36 percent) with known disease recurrence. In four (29 percent) ^18^FDG-PET/CT imaging identified distant metastases, prompting a change from treatment with curative intent to palliative care. Additionally, of the eight ^18^FDG-PET/CT scans completed in five patients to assess treatment response, there was one case of nonresponsive progressive disease correctly identified by ^18^FDG-PET/CT, one patient had stable disease, and three were responsive to treatment. None of these patients had clearly identifiable disease by conventional CT imaging at baseline.

The authors concluded that the use of ^18^FDG-PET/CT was most valuable in assessment of patients with rising CA-125 levels despite negative or equivocal CT scans. They found ^18^FDG-PET/CT to be useful in optimal selection of patients for planning of appropriate surgery and radiation therapy.

This retrospective study was determined to be of high quality. The spectrum of participants and their selection criteria were clearly defined. In addition, the choice and execution of the reference standard, the description of the ^18^FDG-PET/CT imaging procedure and reporting intermediate test results were well detailed. However, due to the retrospective nature of the study, there was no blinded interpretation of either the ^18^FDG-PET/CT scans or the reference standards. The reference standard used to verify disease status consisted of a combination of methods (histological, clinical followup, surgical findings), which raises concerns about the possibility of verification bias.

#### 5.3.3 ^18^FDG-PET and as part of a management strategy in ovarian cancer

None of the studies evaluated ^18^FDG-PET/CT as part of a management strategy. Kim et al. 130 retrospectively assessed the value of ^18^FDG-PET compared to second-look laparotomy (SLL) in the prognosis and detection of recurrences in patients with advanced ovarian cancer following primary chemotherapy. The study population consisted of 55 patients aged 25 to 78 years of age (mean age: 49.2, SD = 12.1), primarily with stage III (49 percent) and IV (44 percent). All patients were treated with a regime of chemotherapy, following which they were divided into two groups for followup. One group (n = 30) underwent SLL while the second (n = 25) underwent ^18^FDG-PET imaging during the followup period. The ^18^FDG-PET was performed a median of 6.8 months after the initial laparotomy and was visually interpreted by two nuclear physicians. Malignancy status was based on quantitative assessment by calculation of SUV values. The median length of followup for both groups was 35 months, and disease recurrence was verified by a variety of methods, including histology, physical exam, additional imaging, and CA-125 levels. The prognostic indicators investigated were the progression free interval, the disease free interval and the incidence of disease recurrence.

Overall, there was evidence of recurrence of ovarian cancer in 37 patients (67 percent). In the ^18^FDG-PET group there were 17 cases with recurrent cancer; of these, 13 (76 percent) were detected by ^18^FDG-PET. There were no significant differences in prognostic indicators between the two groups. When the progression-free interval was compared between the two groups overall, there was no significant difference in the duration of the disease free period. The same was true for the disease-free interval for the subset of patients found to be negative or positive for recurrent disease in either the ^18^FDG-PET or SLL group.

The authors concluded that neither SLL nor ^18^FDG-PET was clearly advantageous for indicating disease prognosis and that ^18^FDG-PET can be used as an alternate followup modality for patients with ovarian cancer.

Overall, this study was determined to be of low quality. The retrospective nature of the prognostic indicator portion of the research, and the lack of a definitive method for determining of an ^18^FDG-uptake positive lesion were some areas of concern. As there was no clear definition of a positive lesion, the study was subject to threshold bias due to variation in interpretation among assessors. Additionally, there was no uniform reference standard administered to the participants, introducing the possibility of verification bias. Outcomes were adequately described and there was an appropriate description of the general characteristics of the participants. As well, all the patients were accounting for. Detailed inclusion criteria are lacking, which makes it difficult to rule out the potential for participant selection bias.

##### Summary of the results

There were five studies of moderate to high methodological quality that evaluated the use of ^18^FDG-PET/CT 75,89,126-128 to assess the restaging126-128 or recurrence75,89 of ovarian cancer. The five studies consistently demonstrated that ^18^FDG-PET/CT altered management plans in an important proportion of patients. The change in management varied, but slightly more often resulted in more aggressive treatment. Only study130 of poor quality examined the effect of ^18^FDG-PET on patient-centered outcomes and prognosis and prohibited any definitive conclusions.

Table 22 provides a summary of the main findings and the types of bias that affected the evidence on the diagnostic thinking impact and effect on patient-centered outcomes of ^18^FDG-PET and ^18^FDG-PET/CT for ovarian cancer.

Table 22 Main findings and types of bias that affected the evidence on the diagnostic thinking impact and effect on patient-centered outcomes of ^18^FDG-PET and ^18^FDG-PET/CT for ovarian cancer

Study | Results of FDG-PET imaging on patient diagnosis, treatment and outcomes | Types of bias
Chung 2007^75^ Study type: Prospective | Management decision: Treatment and diagnostic imaging impact Management strategy changed 19/77 cases (25%) 11 cases without clinical symptoms or abnormal CA-125 were changed from observation to chemotherapy (Treatment) 8 cases with elevated CA-125 had negative PET/CT, so additional diagnostic tests were cancelled (Diagnostics) | Disease progression bias (unclear) Verification bias (>1 RS) Review bias (RS, unclear if blinded)
Kim 2004^130^ Study type: Retrospective | Patient centered outcomes and prognosis: Progression-free interval: PET: 28.8 mo (SD 12.7 m) for 25 cases; SLL: 30.6 mo (SD 13.7 mo) for 30 cases Disease free interval in pts. with negative test results: PET: 40.5 mo (SD 11.6 mo); SLL: 48.6 mo (SD 12.1 mo) Disease free interval in pts. with positive test results: PET: 23.7 mo (SD 5.3 mo); SLL: 26.2 mo (SD 6.7 mo) | Selection bias (unclear) Review bias (RS, unclear if blinded)
Mangili 2007^126^ Study type: Retrospective | Management decision: Treatment and diagnostic imaging impact Management strategy changed 14/32 cases (44%) Changed from observation to treatment or further diagnostics (n = 6) Changed to surgery (n = 3) Underwent further diagnostic examination (n = 2) Changed to chemotherapy (n = 1) Treatment modality changed (n = 8) Surgery to chemotherapy (n = 3) Diagnostic surgery to chemotherapy (n = 3) Chemotherapy to surgery (n = 1) Chemotherapy to additional diagnostic examination (n = 1) | Selection bias (unclear) Disease progression bias (unclear) Verification bias (>1 RS) Review bias (RS, unclear if blinded)
Simcock 2006^127^ Study type: Prospective | Management decision: Treatment 32 cases (33 PET/CT scans) had a high impact of on management (57%) Observation changed to treatment (n = 7) Active treatment changed to observation (n = 6) Surgery changed to chemotherapy (n = 6) Biopsy changed to treatment (e.g., chemotherapy) (n = 4) Changed between various other treatment modalities (n = 8) (e.g., radiation, chemotherapy, surgery) Changed from treatment to biopsy (n = 1) 29 PET/CT scans had a low impact of on management | Spectrum bias (possible) Selection bias (unclear) Disease progression bias (lengthy interval) Verification bias (>1 RS) Review bias (RS unblinded)
Soussan 2008^128^ Study type: Prospective | Management decision: Treatment 16 cases had their diagnosis altered by PET (52%) Upstaged (n = 11); downstaged (n = 4); different disease distribution (n = 1) Management strategy changed 10/29 (34%) Changed from observation to chemotherapy (n = 6) Additional treatment modality added to care plan (n = 2) Changed from chemotherapy to observation (n = 1) | Spectrum bias (possible) Selection bias (unclear) Review bias (RS, not blinded)
Thrall M 2007^89^ Study type: Retrospective | Management decision: Treatment and diagnostic imaging impact Assisted treatment planning of known recurrences 14/39 (36%) Changed from treatment to palliative (n = 4) Assisted with treatment modality plan (n = 10) In cases with no clinical symptoms and normal CA-125, 3 recurrences identified by PET (8% of population) Negative PET allowed cancellation of SSL in 4 surveillance cases | Disease progression bias (lengthy interval) Verification bias (>1 RS) Review bias (RS, not blinded)

CA-125 = cancer antigen 125; CT = computed tomography; FDG = fluorodeoxyglucose F18; mo = months; PET = positron emission tomography; pts. = patients; RS = reference standard; SLL = second-look laparotomy

## 6 Pancreatic Cancer

### 6.1 Background

In 2008 there will be an estimated 37,680 new cases of pancreatic cancer and an estimated 34,290 deaths from the same disease. 133 In 2006 pancreatic cancer was the fourth leading cause of cancer deaths in the United States with a survival rate of four percent. 152 The majority of cases occur in people over the age of 50 and the median age at diagnosis is 72 years. Screening for pancreatic cancer is difficult primarily because there are no tumor markers that can be screened at an early stage of disease. 153

Pancreatic cancers are staged using both the TNM classification and by clinical assessment (i.e., resectable, locally advanced or metastatic). 153 Assignment of the disease stage is typically determined by a combination of history and physical examination, coupled with CT imaging. In patients deemed to be at high risk for metastasis or for whom the staging is indeterminate, the diagnosis is confirmed by fine needle aspiration or laparoscopy.

The majority of pancreatic cancers are diagnosed at a late stage of disease hampering efforts to provide curative therapy. Early symptoms may include weight loss, jaundice, pain, anorexia, dark urine, nausea, vomiting, and weakness. 152 The majority of patients are treated with palliative care at diagnosis although up to 20 percent of patients present with surgically resectable disease. 154 Painless obstructive jaundice has traditionally been associated with resectable disease. 152 For those patients optimally staged and who have surgery, only 20 percent are expected to survive to 5 years. 154 Chemotherapy has shown to be ineffective in treating metastatic disease and has only limited palliative benefit. 154 Surgical resection remains the only treatment that is potentially curative. 152

Diagnosing pancreatic cancer at an early stage is critical to providing curative therapy. Research on the molecular aspects of the disease has observed common genetic changes in pancreatic cancer cells which may be useful in developing future screening and treatment technologies. 153 Ultrasonography is often the first diagnostic test performed when patients present with suspected disease with a sensitivity of 95 percent in tumors greater than 3 centimeters. 155 Sensitivity decreases with smaller tumors. 155 Conventional CT is also used for initial imaging; dual-phase helical CT scans have the highest sensitivity (98 percent) in detecting pancreatic malignancies and metastases. 152

### 6.2 Importance of Key Questions in the Clinical Management of Pancreatic Cancer

The high mortality rates of pancreatic cancer are associated with the lack of specificity of symptoms that lead to late presentations at the time of diagnosis, the aggressive nature of the disease, and the limitations of current diagnostic procedures. Accurate staging, particularly identification of distant metastases, is of paramount importance in order to properly select patients who are the most likely to benefit from surgery. Currently, dynamic CT or endoscopic pancreatocholangiography are used in the diagnosis of patients with suspected pancreatic cancer. Mass-forming pancreatitis occurs when the pancreatitis-associated inflammation affects a portion of the pancreas, creating the appearance of a mass on imaging tests. Chronic pancreatitis is a risk factor for pancreatic cancer, so mass-forming pancreatitis is frequently found in those patients with suspected pancreatic cancer. Differential diagnosis between pancreatic cancer and pancreatitis is a common problem with imaging modalities. Another problem of CT scans relates to monitoring the treatment response. Pancreatic cancer usually presents cancer cells sparsely scattered in active desmoplastic background and frequently invades major organs including celiac trunk or superior mesenteric vessels with small primary mass. These characteristics of pancreatic cancer make it difficult to determine tumor response following chemotherapy or chemoradiotherapy. Other recent technological advances for the diagnosis of pancreatic cancer include magnetic resonance cholangiopancreatography (MRCP) which may be useful for the noninvasive demonstration of the morphologic contours of the pancreatic duct. However, this tool cannot always detect tumor progression, especially when the tumor is not large enough to be identified accurately, and it is difficult to know the biological activity of the tumor. Early studies have suggested that combined ^18^FDG-PET/CT without contrast enhancement does not provide additional benefit compared to other diagnostic imaging techniques in the diagnosis of pancreatic cancer; 155 but further evidence needs to be evaluated before firm recommendations are made.

### 6.3 Results

Seventeen studies91-107 provided evidence on the use of ^18^FDG-PET or ^18^FDG-PET/CT for pancreatic cancer. All of the studies evaluated the diagnostic accuracy of ^18^FDG-PET or ^18^FDG-PET/CT, and five studies reported on the diagnostic thinking impact of ^18^FDG-PET91,101,103,105 and ^18^FDG-PET/CT. 95 One study91 evaluated the effects of ^18^FDG-PET as part of a management strategy on patient centered outcomes. Finally, one study95 conducted an economic evaluation on the use of ^18^FDG-PET/CT for pancreatic cancer. Characteristics of the populations, conditions of ^18^FDG-PET and ^18^FDG-PET/CT administration, interpretation of results and methodological quality of the studies are summarized in Appendices D to J.

#### 6.3.1 Diagnostic accuracy of ^18^FDG-PET and ^18^FDG-PET/CT in pancreatic cancer

##### Characteristics of the studies

Seventeen studies (fourteen prospective, 91,93-98,100-106 three retrospective92,99,107) evaluated the diagnostic accuracy of ^18^FDG-PET91,92,94,97-107 and ^18^FDG-PET/CT95,96 or both93 on pancreatic cancer. ^18^FDG-PET was used for primary diagnosis in five studies, 94,99,100,102,106 for initial staging in two studies, 101,107 for assessing recurrence in one study, 104 and for both primary diagnosis and staging in six studies. 91,92,97,98,103,105 Two studies used ^18^FDG-PET/CT for both diagnosis and staging, 95,96 while one study used ^18^FDG-PET and ^18^FDG-PET/CT for diagnosis, staging and restaging. 93 The studies contained a total of 1,051 patients with sample sizes ranging from 15 to 112 participants. Participant ages ranged from 21 to 93 years. One study reported the distribution by stage of cancer: CS I = 6 percent, CS II = 23 percent, CS III = 65 percent and CS IV = 6 percent. 104 ^18^FDG-PET was compared to a reference standard that varied across the studies. In fifteen studies the reference standard was either histology/biopsy or clinical followup. 91-101,103-106 Two studies established the final diagnosis of all patients using histology/biopsy. 102,107 One study reported the mean time between last treatment and ^18^FDG-PET as 12 months. 104 Seven studies used a fixed dose of ^18^FDG (5 MCi, 107 120 MBq, 94 200 MBq, 98 370 MBq, 91 400 MBq, 97,102 444 MBq105). Seven studies used a weight-based dose (3 MBq/kg, 100,101 3.7 MBq/kg, 98 4 MBq/kg, 93 5 MBq/kg96,103,104). Three studies reported a dose range for ^18^FDG: 200 to 220 MBq, 106 260 to 370 MBq, 92 350 to 450 MBq. 95 The time between injection and PET scan was 20 minutes, 97 35 to 50 minutes, 102 60 minutes, 91,93-95,98,100,101,105-107 60 to 90 minutes, 96 60 to 120 minutes, 92 and 90 minutes. 103,104 Patients fasted for the following durations: 4 hours, 91,95,107 5 hours, 98,100 6 hours, 93,97,101,106 8 hours, 103,104 12 hours, 94 and overnight. 92,105 Eight studies92,93,96,97,100,103-105 measured glucose levels before administration of ^18^FDG-PET; the maximum glucose level allowed was 10 mmol/L, 97 110 mg/dL, 96,103,104 120 mg/dL, 105 and 200 mg/dL. 93,100 Methods of interpretation of the images were qualitative in three studies93,95,101 and both qualitative and quantitative in fourteen. 91,92,94,96-100,102-107 Scans were interpreted qualitatively using visual analysis. 91-98,100-107 Seven studies reported using SUV, where the criterion for abnormality was SUV > 2.5 g/mL92,105 SUV > 3 g/mL, 98,102 and SUV > 3.5 g/mL. 96,100,103

##### Comparisons

Comparisons for which data were considered for meta-analysis are summarized in Table 23. Pooled data were obtained to evaluate the accuracy of ^18^FDG-PET for both primary diagnosis and staging purposes, and for primary diagnosis purposes separately. Pooled data were also obtained to evaluate the accuracy of ^18^FDG-PET/CT for both the primary diagnosis and staging of pancreatic cancer. Individual data are summarized in Appendix D.

Table 23 Summary of comparisons considered for meta-analyses of the accuracy of ^18^FDG-PET and ^18^FDG-PET/CT for pancreatic cancer

Indication | Studies | Design | Type of PET | Reference standard | Meta-analysis
Primary diagnosis and staging | Bang 2006^91^ | P | FDG-PET | Histology/biopsy or clinical followup | 1. FDG-PET v. histology/biopsy or clinical followup (P studies)91, 93, 96-98, 103,105 2. FDG-PET/CT v. histology/biopsy or clinical followup (P studies)93,95,96
Primary diagnosis and staging | Borbath 2005^92^ | R | FDG-PET | Histology/biopsy or clinical followup | 1. FDG-PET v. histology/biopsy or clinical followup (P studies)91, 93, 96-98, 103,105 2. FDG-PET/CT v. histology/biopsy or clinical followup (P studies)93,95,96
Primary diagnosis and staging | Heinrich 2005^95^ | P | FDG-PET/CT | Histology/biopsy or clinical followup | 1. FDG-PET v. histology/biopsy or clinical followup (P studies)91, 93, 96-98, 103,105 2. FDG-PET/CT v. histology/biopsy or clinical followup (P studies)93,95,96
Primary diagnosis and staging | Lemke 2004^96^ | P | FDG-PET and FDG-PET/CT | Histology/biopsy or clinical followup | 1. FDG-PET v. histology/biopsy or clinical followup (P studies)91, 93, 96-98, 103,105 2. FDG-PET/CT v. histology/biopsy or clinical followup (P studies)93,95,96
Primary diagnosis and staging | Lytras 2005^97^ | P | FDG-PET | Histology/biopsy or clinical followup | 1. FDG-PET v. histology/biopsy or clinical followup (P studies)91, 93, 96-98, 103,105 2. FDG-PET/CT v. histology/biopsy or clinical followup (P studies)93,95,96
Primary diagnosis and staging | Maemura 2006^98^ | P | FDG-PET | Histology/biopsy or clinical followup | 1. FDG-PET v. histology/biopsy or clinical followup (P studies)91, 93, 96-98, 103,105 2. FDG-PET/CT v. histology/biopsy or clinical followup (P studies)93,95,96
Primary diagnosis and staging | Ruf 2006^103^ | P | FDG-PET | Histology/biopsy or clinical followup | 1. FDG-PET v. histology/biopsy or clinical followup (P studies)91, 93, 96-98, 103,105 2. FDG-PET/CT v. histology/biopsy or clinical followup (P studies)93,95,96
Primary diagnosis and staging | Sperti 2007^105^ | P | FDG-PET | Histology/biopsy or clinical followup | 1. FDG-PET v. histology/biopsy or clinical followup (P studies)91, 93, 96-98, 103,105 2. FDG-PET/CT v. histology/biopsy or clinical followup (P studies)93,95,96
Primary diagnosis and staging | Casneuf 2007^93^ | P | FDG-PET and FDG-PET/CT | Histology/biopsy or clinical followup | 1. FDG-PET v. histology/biopsy or clinical followup (P studies)91, 93, 96-98, 103,105 2. FDG-PET/CT v. histology/biopsy or clinical followup (P studies)93,95,96
Primary diagnosis | Giorgi 2004^94^ | P | FDG-PET | Histology/biopsy or clinical followup | 1. FDG-PET v. all comparators (P studies) 94,100,102,106 2. FDG-PET v. histology/biopsy or clinical followup (P studies) 94, 100, 106
Primary diagnosis | Mansour 2006^99^ | R | FDG-PET | Histology/biopsy or clinical followup | 1. FDG-PET v. all comparators (P studies) 94,100,102,106 2. FDG-PET v. histology/biopsy or clinical followup (P studies) 94, 100, 106
Primary diagnosis | Nishiyama 2005^100^ | P | FDG-PET | Histology/biopsy or clinical followup | 1. FDG-PET v. all comparators (P studies) 94,100,102,106 2. FDG-PET v. histology/biopsy or clinical followup (P studies) 94, 100, 106
Primary diagnosis | Rasmussen 2004^102^ | P | FDG-PET | Histology/biopsy | 1. FDG-PET v. all comparators (P studies) 94,100,102,106 2. FDG-PET v. histology/biopsy or clinical followup (P studies) 94, 100, 106
Primary diagnosis | van Kouwen 2005^106^ | P | FDG-PET | Histology/biopsy or clinical followup | 1. FDG-PET v. all comparators (P studies) 94,100,102,106 2. FDG-PET v. histology/biopsy or clinical followup (P studies) 94, 100, 106
Recurrences | Ruf 2005^104^ | P | FDG-PET | Histology/biopsy or clinical followup | No
Staging | Nishiyama 2005^101^ | P | FDG-PET | Histology/biopsy or clinical followup | No
Staging | Wakabayashi 2008^107^ | R | FDG-PET | Histology/biopsy | No

FDG = fluorodeoxyglucose F18; P = prospective; PET=positron emission tomography; R = retrospective

###### 1 ^18^FDG-PET for the primary diagnosis and staging of pancreatic cancer

Reference standard: histology/biopsy or clinical followup; prospective studies. Seven prospective studies91,93,96-98,103,105 totaling 479 participants provided data for a meta-analysis of the diagnostic accuracy of ^18^FDG-PET v. histology/biopsy or clinical followup for the diagnosis and staging of pancreatic cancer. Individual 2x2 table results are presented in Figure 67. Sensitivity ranged from 73 percent97 to 97 percent. 91 Specificity ranged from 41 percent103 to 97 percent. 105

Figure 67 Results from 2x2 tables of individual prospective studies of ^18^FDG-PET v. histology/biopsy or clinical followup for the primary diagnosis and staging of pancreatic cancer

We found that, ^18^FDG-PET had a pooled positive LR of 2.77 (95% CI = 1.62, 4.73) and a pooled negative LR of 0.19 (95% CI = 0.10, 0.34) to accurately diagnose and identify the stage of pancreatic cancer (Figures 68 and 69). There was considerable heterogeneity in the positive (p = 0.003; I^2^ = 70 percent) and negative (p = 0.004, I^2^ = 68 percent) LRs across the studies, which limits our ability to draw conclusions about the overall accuracy of ^18^FDG-PET.

Figure 68 Meta-analysis of the positive likelihood ratio of ^18^FDG-PET v. histology/biopsy or clinical followup for the primary diagnosis and staging of pancreatic cancer (prospective studies)

Figure 68 a meta-graph depicting the positive likelihood ratio of FDG-PET versus histology/biopsy or clinical follow-up for the primary diagnosis and staging of pancreatic cancer. The figure is described in Chapter 6. Seven studies contributed data from 479 participants. The pooled positive likelihood ratio to rule in the disease was 2.77 (95% confidence interval 1.62, 4.73). There was substantial heterogeneity with an I2 of 70%.

Figure 69 Meta-analysis of the negative likelihood ratio of ^18^FDG-PET v. histology/biopsy or clinical followup for the primary diagnosis and staging of pancreatic cancer (prospective studies)

Figure 69 is a meta-graph depicting the negative likelihood ratio of FDG-PET versus histology/biopsy or clinical follow-up for the primary diagnosis and staging of pancreatic cancer. The figure is described in Chapter 6. Seven studies contributed data from 479 participants. The pooled negative likelihood ratio to rule out the disease was 0.19 (95% confidence interval 0.10, 0.34). There was substantial heterogeneity with an I2 of 68%.

Figure 70 shows the estimates of sensitivity and 1-specificity plotted in ROC space for ^18^FDG-PET v. histology/biopsy or clinical followup for the primary diagnosis and staging of pancreatic cancer based on prospective studies.

Figure 70 Summary ROC plot of ^18^FDG-PET v. histology/biopsy or clinical followup for the primary diagnosis and staging of pancreatic cancer (prospective studies)

Figure 70 is a summary receiver operating characteristics plot of FDG-PET versus histology/biopsy or clinical follow-up for the primary diagnosis and staging of pancreatic cancer. The figure shows the paired estimates of sensitivity and 1-specificity for each of the seven included studies. The curve appears near the top left hand corner.

###### 2 ^18^FDG-PET/CT for the primary diagnosis and staging of pancreatic cancer

Reference standard: histology/biopsy or clinical followup; prospective studies. Three prospective studies93,95,96 totaling 193 participants provided data for a meta-analysis of the diagnostic accuracy of ^18^FDG-PET/CT v. histology/biopsy or clinical followup for the diagnosis and staging of pancreatic cancer. Individual 2x2 table results are presented in Figure 71. Sensitivity was 89 percent in all the individual studies. Specificity ranged from 64 percent96 to 90 percent. 93

Figure 71 Results from 2x2 tables of individual prospective studies of ^18^FDG-PET/CT v. histology/biopsy or clinical followup for the primary diagnosis and staging of pancreatic cancer

We found that ^18^FDG-PET/CT had a pooled positive LR of 2.69 (95% CI = 1.84, 3.94) and a pooled negative LR of 0.16 (95% CI = 0.10, 0.26) to accurately diagnose and identify the stage of the disease (Figures 72 and 73). Both positive and negative LRs were homogeneous across the studies.

Figure 72 Meta-analysis of the positive likelihood ratio of ^18^FDG-PET/CT v. histology/biopsy or clinical followup for the primary diagnosis and staging of pancreatic cancer (prospective studies)

Figure 72 is a meta-graph depicting the positive likelihood ratio of FDG-PET/CT versus histology/biopsy or clinical follow-up for the primary diagnosis and staging of pancreatic cancer. The figure is described in Chapter 6. Three studies contributed data from 193 participants. The pooled positive likelihood ratio to rule in the disease was 2.69 (95% confidence interval 1.84, 3.94). The positive likelihood ratios were homogeneous across studies (I2=0%).

Figure 73 Meta-analysis of the negative likelihood ratio of ^18^FDG-PET/CT v. histology/biopsy or clinical followup for the primary diagnosis and staging of pancreatic cancer (prospective studies)

Figure 73 is a meta-graph depicting the negative likelihood ratio of FDG-PET/CT versus histology/biopsy or clinical follow-up for the primary diagnosis and staging of pancreatic cancer. The figure is described in Chapter 6. Three studies contributed data from 193 participants. The pooled negative likelihood ratio to rule out the disease was 0.16 (95% confidence interval 0.10, 0.26). The negative likelihood ratios were homogeneous across studies (I2=0%).

Figure 74 shows the estimates of sensitivity and 1-specificity plotted in ROC space for ^18^FDG-PET/CT v. histology/biopsy or clinical followup for the primary diagnosis and staging of pancreatic cancer, based on prospective studies.

Figure 74 Summary ROC plot of ^18^FDG-PET/CT v. histology/biopsy or clinical followup for the primary diagnosis and staging of pancreatic cancer (prospective studies)

Figure 74 is a summary receiver operating characteristics plot of FDG-PET/CT versus histology/biopsy or clinical follow-up for the primary diagnosis and staging of pancreatic cancer. The figure shows the paired estimates of sensitivity and 1-specificity for each of the three included studies. The curve appears near the top left hand corner of the receiver operating characteristics space.

###### 3 ^18^FDG-PET for the primary diagnosis of pancreatic cancer

Reference standard: any; prospective studies. Four prospective studies94,100,102,106 totaling 230 participants provided data for a meta-analysis of the diagnostic accuracy of ^18^FDG-PET compared to a variety of reference standards for the primary diagnosis of pancreatic cancer. Individual 2x2 table results are presented in Figure 75. Sensitivity ranged from 69 percent94 to 91 percent. 106 Specificity ranged from 65 percent100 to 100 percent. 94

Figure 75 Results from 2x2 tables of individual prospective studies of ^18^FDG-PET v. any reference standard for the primary diagnosis of pancreatic cancer

We found that, when all the reference standards were considered, ^18^FDG-PET had a pooled positive LR of 4.28 (95% CI = 2.07, 8.86) and a pooled negative LR of 0.21 (95% CI = 0.12, 0.40) to accurately diagnose the disease (Figures 76 and 77). There was moderate heterogeneity in the positive (p = 0.07; I^2^ = 58 percent) and negative (p = 0.16, I^2^ = 42 percent) LRs across the studies, making it difficult to draw conclusions about the overall accuracy of ^18^FDG-PET.

Figure 76 Meta-analysis of the positive likelihood ratio of ^18^FDG-PET v. any reference standard for the primary diagnosis of pancreatic cancer (prospective studies)

Figure 76 is a meta-graph depicting the positive likelihood ratio of FDG-PET versus all reference standards for the primary diagnosis of pancreatic cancer. The figure is described in Chapter 6. Four studies contributed data from 230 participants. The pooled positive likelihood ratio to rule in the disease was 4.28 (95% confidence interval 2.07, 8.86). There was moderate heterogeneity in the positive likelihood ratios with an I2 of 58%.

Figure 77 Meta-analysis of the negative likelihood ratio of ^18^FDG-PET v. any reference standard for the primary diagnosis of pancreatic cancer (prospective studies)

Figure 77 is a meta-graph depicting the negative likelihood ratio of 18FDG-PET versus al reference standards for the primary diagnosis of pancreatic cancer. The figure is described in Chapter 6. Four studies contributed data from 230 participants. The pooled negative likelihood ratio to rule out the disease was 0.21 (95% confidence interval 0.12, 0.40). There was moderate heterogeneity in the negative likelihood ratios with an I2 of 42%.

Figure 78 shows the estimates of sensitivity and 1-specificity plotted in ROC space for ^18^FDG-PET v. all the reference standards for the primary diagnosis of pancreatic cancer, based on prospective studies.

Figure 78 Summary ROC plot of ^18^FDG-PET v. any reference standard for the primary diagnosis of pancreatic cancer (prospective studies)

Figure 78 is a summary receiver operating characteristics plot of 18FDG-PET/CT versus all reference standards for the primary diagnosis of pancreatic cancer. The figure shows the paired estimates of sensitivity and 1-specificity for each of the four included studies. The curve appears near the top left hand corner of the receiver operating characteristics space.

Reference standard: histology/biopsy or clinical followup, prospective studies (subgroup analysis). Three prospective studies94,100,106 totaling 210 participants provided data for a subgroup analysis of the diagnostic accuracy of ^18^FDG-PET when only histology/biopsy or clinical followup was used as the reference standard for the primary diagnosis of pancreatic cancer. Individual 2x2 table results are presented in Figure 79. Sensitivity ranged from 69 percent94 to 91 percent. 106 Specificity ranged from 41 percent103 to 97 percent. 105

Figure 79 Results from 2x2 tables of individual prospective studies of ^18^FDG-PET v. histology/biopsy or clinical followup for the primary diagnosis of pancreatic cancer

When ^18^FDG-PET was compared to histology/biopsy or clinical followup for the primary diagnosis of pancreatic cancer, the pooled positive LR was 4.11 (95% CI = 1.74, 9.70) and the pooled negative LR was 0.9 (95% CI = 0.09, 0.44) (Figures 80 and 81). There was considerable heterogeneity in the positive (p = 0.03; I^2^ = 71 percent) and negative (p = 0.09, I^2^ = 58 percent) LRs across the studies, making it difficult to draw conclusions about the overall accuracy of ^18^FDG-PET.

Figure 80 Meta-analysis of the positive likelihood ratio of ^18^FDG-PET v. histology/biopsy or clinical followup for the primary diagnosis of pancreatic cancer (prospective studies)

Figure 80 is a meta-graph depicting the positive likelihood ratio of 18FDG-PET versus histology/biopsy or clinical followup for the primary diagnosis of pancreatic cancer. This figure is described in Chapter 6. The pooled positive likelihood ratio was 4.11 (95% confidence interval 1.74, 9.70). There was considerable heterogeneity in the positive (p = 0.03; I2 = 71 percent) likelihood ratio across the studies.

Figure 81 Meta-analysis of the negative likelihood ratio of ^18^FDG-PET v. histology/biopsy or clinical followup for the primary diagnosis of pancreatic cancer (prospective studies)

Figure 81 is a meta-graph depicting the positive likelihood ratio of 18FDG-PET versus histology/biopsy or clinical followup for the primary diagnosis of pancreatic cancer. This figure is described in Chapter 6. The pooled negative likelihood ratio was 0.9 (95% confidence interval 0.09, 0.44). There was considerable heterogeneity in the negative (p = 0.09, I2 = 58 percent) likelihood ratio across the studies.

Figure 82 shows the estimates of sensitivity and 1-specificity plotted in ROC space for ^18^FDG-PET v. histology/biopsy or clinical followup for the primary diagnosis of pancreatic cancer

Figure 82 Summary ROC plot of ^18^FDG-PET v. histology/biopsy or clinical followup for the primary diagnosis of pancreatic cancer (prospective studies)

Figure 82 is a summary receiver operating characteristics plot that describes of 18FDG-PET versus histology/biopsy or clinical followup for the primary diagnosis of pancreatic cancer. The figure shows the paired estimates of sensitivity and 1-specificity for each of the three included studies. Sensitivity is plotted on the X-axis and specificity is plotted on the Y-axis. The curve appears near the top left hand corner of the receiver operating characteristics space.

##### Summary of the results

Meta-analyses were calculated to evaluate the accuracy of ^18^FDG-PET and ^18^FDG-PET/CT for both the primary diagnosis and staging of pancreatic cancer (Table 24). The findings were consistently significant, suggesting that both ^18^FDG-PET and ^18^FDG-PET/CT are useful for primary diagnosis and staging. However, the pooled results are, for the most part, heterogeneous; therefore the magnitude of the effect is uncertain. Further, there is no clear evidence for the choice of ^18^FDG-PET v. ^18^FDG-PET/CT, since the observed heterogeneity indicates considerable uncertainty in these estimates. When ^18^FDG-PET was evaluated for primary diagnosis purposes only, the positive likelihood radio was slightly better for ruling in the disease, but the negative LR remained almost the same. Evidence on the use of ^18^FDG-PET for recurrences and staging is derived from individual study data and therefore, firm conclusions about the utility of ^18^FDG-PET for these indications cannot be made.

Table 24 Results of meta-analyses of the accuracy of ^18^FDG-PET and ^18^FDG-PET/CT for pancreatic cancer

PET Purpose | Type of PET | Reference standard | Design | Studies | N | Effect estimate M-H, Random, 95% CI
Primary diagnosis/staging | FDG-PET | Histology/biopsy or clinical followup | P | 7 | 479 | PLR = 2.77 [1.62, 4.73]
Primary diagnosis/staging | FDG-PET | Histology/biopsy or clinical followup | P | 7 | 479 | NLR = 0.19 [0.10, 0.34]
Primary diagnosis/staging | FDG-PET/CT | Histology/biopsy or clinical followup | P | 3 | 193 | PLR = 2.69 [1.84, 3.94]
Primary diagnosis/staging | FDG-PET/CT | Histology/biopsy or clinical followup | P | 3 | 193 | NLR = 0.16 [0.10, 0.26]
Primary diagnosis | FDG-PET | Any reference standard | P | 4 | 230 | PLR = 4.28 [2.07, 8.86]
Primary diagnosis | FDG-PET | Any reference standard | P | 4 | 230 | NLR = 0.21 [0.12, 0.40]
Primary diagnosis | FDG-PET | Histology/biopsy or clinical followup | P | 3 | 210 | PLR = 4.11 [1.74, 9.70]
Primary diagnosis | FDG-PET | Histology/biopsy or clinical followup | P | 3 | 210 | NLR = 0.20 [0.09, 0.44]

CI = confidence interval; FDG = fluorodeoxyglucose F18; M-H = Mantel Hantzel; NLR = negative likelihood ratio; P = prospective; PET = positron emission tomography; PLR = positive likelihood ratio

#### 6.3.2 Diagnostic thinking impact of ^18^FDG-PET and ^18^FDG-PET/CT on physician decision making with respect to diagnosis and management strategy for patients with pancreatic cancer

Five studies evaluated the diagnostic thinking impact of ^18^FDG-PET91,101,103,105 and ^18^FDG-PET/CT. 95 with regards to patient management and diagnostic work-up of pancreatic cancer. The imaging by ^18^FDG-PET was used for both initial diagnostic (^18^FDG-PET, 3 studies;91,103,105 ^18^FDG-PET/CT, 1 study95 and staging purposes (^18^FDG-PET, 4 studies;91,101,103,105 ^18^FDG-PET/CT, 1 study95).

Bang et al. 91 evaluated the clinical impact of using ^18^FDG-PET on the diagnosis and staging of pancreatic cancer and on monitoring tumor response to chemoradiation. One hundred and two patients undergoing evaluation for suspected primary pancreatic cancer were prospectively enrolled in this study. Of these, 93 patients with confirmed pancreatic cancer were assessed for the diagnostic thinking impact of ^18^FDG-PET. ^18^FDG-PET findings led to a change in the pre-treatment staging in 25 patients (27 percent). For 20 patients, the treatment management was altered by changing the resectability status. The majority of changes (17/20) were due to the identification of previously unsuspected metastases, and resulted in the cancellation of previously planned surgical resection. Of particular note, 8/17 of the newly identified metastases were sites in the liver and had not been detected by the initial dynamic CT scan. Three cases previously considered un-resectable were downstaged and considered to be treatable following ^18^FDG-PET. These findings were subsequently confirmed by biopsy.

The authors concluded that ^18^FDG-PET was a sensitive and specific imaging modality which would be a good adjunct to conventional imaging techniques. They noted that it was particularly sensitive in the detection of small unsuspected hepatic lesions relative to conventional imaging by CT scan or ultrasonography. ^18^FDG-PET was useful in the reassessment of conventionally staged tumors and treatment decisions regarding resectability were amended, which allowed for the cancellation of unnecessary surgeries.

This prospective study was determined to be of moderate quality. Methodological strengths included: a clear description of the selection criteria, as well as sufficient description of the choice of the standard, blinded interpretation of the index test, accounting for all participants and intermediate test results. Weaknesses included a partial description of the spectrum of included patients, as well as an incomplete description of the execution of the index test or reference standards and lack of clarity about the period between the execution of ^18^FDG-PET and the reference standard. These weaknesses could have led to spectrum and disease progression bias. Additionally, there was more than one standard used for confirmation of the true disease status, which may have introduced verification bias. Of particular concern is that the physicians interpreting the results of the reference standard were not described as blinded to the results of the ^18^FDG-PET, possibly introducing review bias.

Heinrich et al. 95 investigated the treatment decision impact of integrated ^18^FDG-PET/CT on the diagnosis and staging of pancreatic cancer. Fifty-nine consecutive patients with focal lesions in the pancreas were prospectively enrolled in this study. Of the 37 patients who were judged to have resectable pancreatic cancer, treatment management changed in six patients (16 percent) as a result of ^18^FDG-PET/CT findings. In addition, of the 46 patients who were found by the reference standard to have malignant pancreatic lesions, ^18^FDG-PET/CT findings changed management in 15 patients (33 percent). ^18^FDG-PET/CT resulted in changes to significantly more treatment decisions compared to standard staging (9/46 cases; 20 percent [p = 0.03]). ^18^FDG-PET/CT also identified 17 benign lesions. Although the detection of these lesions did not impact treatment, scan results occasionally prompted further diagnostic evaluation, including biopsies. In addition, ^18^FDG-PET/CT improved detection of distant metastases; these were diagnosed in 13 patients, of which five were solely identified by ^18^FDG-PET/CT. In two patients, cancer was found by ^18^FDG-PET/CT only and had not been previously identified on physical examination. As a result, the surgical treatment was changed for both patients.

The authors concluded that ^18^FDG-PET/CT significantly changed the overall management of patients with pancreatic cancer when compared to standard staging. Based on their clinical and economic evaluation, the authors stated that preoperative staging use of ^18^FDG-PET/CT is beneficial and may advance standard staging.

This prospective study of consecutively enrolled patients was determined to be of moderate quality. The methodological strengths of this study include a short time period between the ^18^FDG-PET/CT and reference standard, as well as sufficient description of the choice of the standard, the execution of the index test, accounting for all participants and intermediate test results. However, the execution of the reference standard, spectrum of patients included in the study, and selection criteria were not described in adequate detail. Thus, both spectrum bias and selection bias may have affected the results of this study. Furthermore, all patients did not receive the same reference standard, which may have introduced verification bias. Of particular concern is that the physicians interpreting the results of the reference standard were not blinded to the results of the ^18^FDG-PET/CT, and blinding of the ^18^FDG-PET/CT interpretation was not clearly reported.

Nishiyama et al. 101 examined the impact of ^18^FDG-PET used in the diagnosis and staging of pancreatic cancer on treatment decisions. Forty-two consecutive patients with histopathologically confirmed pancreatic cancer and no previous treatment were prospectively enrolled. ^18^FDG-PET had an impact on treatment management in 5 of 42 patients (12 percent). Three patients were altered from curative to palliative treatment, while two other patients were changed from palliative to curative treatment.

The authors recommended routine ^18^FDG-PET for preoperative staging of patients with potentially resectable pancreatic cancer. This could result in a marked increased detection of metastases. However, the authors also stated the CT and ^18^FDG-PET have a complementary role in the identification of distant metastases and ^18^FDG-PET alone does not provide sufficient information for staging. This article was written prior to readily available access to integrated ^18^FDG-PET/CT scanners and the authors speculated that such hybrid scanners would increase detection and localization.

This prospective study of consecutively enrolled patients was assessed to be of high quality. Components that were well addressed included description of the spectrum of patients, choice of reference standard, details of the execution of index test and reference standard, and clear reporting of all participants and test results. In addition, the time interval between the index and reference standard was judged to be sufficiently brief to avoid significant change in patients’ conditions. Although all patients received verification of their disease status by a reference test, they did not all receive the same standard, introducing the possibility of verification bias. The index test was interpreted without knowledge of the result of the reference standard, but the interpretation of the reference standard was unblinded. An additional weakness was the limited description of the selection criteria, raising uncertainty as to what these criteria were and how they were applied.

Ruf et al. 103 evaluated the treatment decision influence of ^18^FDG-PET/MRI fusion on the diagnosis and staging of pancreatic cancer. The study prospectively enrolled 32 adult patients suspected of having a pancreatic mass. In 8 of 32 patients (25 percent), topographical assignment and interpretation of ^18^FDG-PET foci was improved through fusion of ^18^FDG-PET and MRI images. However, image fusion only resulted in a change of treatment in one patient, for whom surgery was performed with a curative intent. The remaining seven patients did not have a change in treatment as a result of ^18^FDG-PET/MRI image fusion due to inoperability (n = 2), other medical reasons (n = 1), other metastases being present in other regions thus preventing curative surgery (n = 2), and image fusion having no influence on the planned palliative surgery (n = 2).

The authors concluded the ^18^FDG-PET/MRI improved assignment of foci but had minimal therapeutic consequences. This was mainly attributed to the small number of patients most of whom had multiple lesions that prevented curative treatment. It is possible that a larger treatment impact would be observed in patients with small, resectable primaries and only peripancreatic lymph node manifestations.

This prospective study was assessed to be of moderate quality. Many elements of the study were well described, including the selection criteria, choice of reference standard, as well as the period between execution of the index test and reference standard. In addition, intermediate test results and study withdrawals were reported. The spectrum of patients included in the study was not well documented and it was unclear from where they were recruited or referred. Therefore, it is possible that spectrum bias may have occurred. Also, both the index and reference standard tests were interpreted in an unblinded manner, thereby increasing the risk of review bias in this study.

A final study by Sperti et al. 105 investigated the treatment decision impact of integrated ^18^FDG-PET on the diagnosis of pancreatic cancer. A prospective sample of 71 patients with suspected intraductal papillary mucinous neoplasms (IPMN) of the pancreas underwent ^18^FDG-PET scans. Of these, 64 had ^18^FDG-PET scans available and were included in the analysis. The treatment plan was substantially altered in 44 (69 percent). Positive ^18^FDG-PET results impacted treatment decisions in 10 patients; seven (11 percent) underwent surgical resection, two patients with hepatic metastases not evident in CT avoided laparotomy, and one patient underwent resection of a borderline IPMN associated with unsuspected colon cancer. Negative ^18^FDG-PET results prompted changes in treatment management in 34 patients; 19 (30 percent) were scheduled for followup and 15 (23 percent) underwent more limited resection (six had a more conservative resection and nine avoided splenectomy).

The authors concluded that ^18^FDG-PET was superior to conventional imaging techniques in its ability to identify patients with pancreatic IPMN for surgical intervention or followup. This is particularly true for asymptomatic patients.

This prospective study was assessed to be of high quality. The spectrum of patients was representative of those who would receive this test in practice and the choice of reference standard was appropriate and independent of the index test. There was good reporting of the execution of the index and reference tests, any intermediate test results and study withdrawals. Both the index test and reference standard were interpreted in a blinded manner. Although all patients received a reference standard, this reference was not the same for all patients; some received histological verification of disease and others clinical followup. Therefore, verification bias may have affected the results of this study. The main weaknesses of the study were lack of clarity on the duration between index and reference tests and only partial description of the selection criteria.

#### 6.3.3 ^18^FDG-PET as part of a management strategy in pancreatic cancer

Bang et al. 91 additionally examined using ^18^FDG-PET to monitor patient response to concurrent chemoradiation. The characteristics of the study population (n=93) and quality have been discussed in detail in the section above. The outcomes of a subset of 15 (16 percent) patients diagnosed with pancreatic cancer who were followed with pre- and post-treatment imaging were included in this analysis. The remaining 78 patients did not receive concurrent chemoradiation for reasons not specified. ^18^FDG-PET was compared to dynamic CT scans, serial serum CA19-9 measurements and a clinical benefit score determined by a series of quantitative and qualitative measurements (intensity of pain, analgesic use, Karnofsky performance scale and body weight). The authors evaluated whether treatment response could be determined by followup CT and ^18^FDG-PET assessments in all patients, and correlated patient response status with the time to disease progression. Response was judged as complete if disease sites disappeared and partial if lesions were reduced in size (CT scan) or ^18^FDG uptake (^18^FDG-PET).

No patients were considered to be “responders” based on the CT scan results; however, five cases were judged to be “responders” by ^18^FDG-PET. The time to disease progression was significantly longer in the ^18^FDG-PET “responders” group as compared to the ^18^FDG-PET “non-responders.” The mean time to progression in the “responders” was 399 days (95% CI, 282 to 526) v. 233 days (95% CI, 181 to 235) in the “non-responders.” The clinical benefit score and serial changes in CA19-9 did not correlate significantly with the results of either imaging modality.

The authors concluded that ^18^FDG-PET was more accurate than dynamic CT scan for determining treatment response to concurrent chemoradiotherapy. Neither clinical benefit score nor serum CA19-9 measurements were found to predict treatment response. However, it should be noted that while the overall study sample was large, there was only a small number of patients (n = 15) included in this analysis of ^18^FDG-PET impact on management strategy relating patient-centered outcomes.

#### 6.3.4 Cost-effectiveness of ^18^FDG-PET/CT for pancreatic cancer

Heinrich et al. 95 examined cost savings with use of ^18^FDG-PET/CT in addition to routine diagnostic procedures to determine staging and eligibility for surgery among patients with presumed resectable pancreatic cancer. The authors conducted a secondary analysis of patient data that had been collected as part of a phase II clinical trial evaluating neoadjuvant chemotherapy for resectable pancreatic cancer. The sample included 59 patients who had a focal pancreatic lesion or suspected pancreatic cancer and had undergone ^18^FDG-PET/CT. Accuracy data for the diagnostic tests were derived from the trial data; diagnosis was confirmed through intraoperative findings and results of histology or biopsy. Cost data were obtained from the hospital accounting department. A cost-benefit analysis considering direct costs during the staging and peri-operative period was conducted from a hospital perspective. Among the 59 patients, ^18^FDG-PET/CT detected metastasis in five patients who were then deemed ineligible for surgery. This resulted in cost savings of US$1,066 per patient. Cost savings were higher (US$2,844 per patient) with selective use of ^18^FDG-PET/CT among patients identified as surgical candidates through standard, routine staging procedures. Results of sensitivity analyses for shorter length of stay, type of fine-needle aspiration, and surgical confirmation of metastasis were consistent in demonstrating cost savings. The study was based on Swiss data and practice patterns; however, the authors suggested that results may be generalizable to other centers in Europe and the United States. The authors presented results and conclusions within the stated objectives and given data. The primary and sensitivity analyses were restricted to a limited number of costs and outcomes.

##### Summary of the results

Five prospective studies of moderate to high quality (four on ^18^FDG-PET91,101,103,105 and one95 on ^18^FDG-PET/CT) provided evidence on the diagnostic thinking impact of ^18^FDG-PET and ^18^FDG-PET/CT). One study91 evaluated the use of ^18^FDG-PET as part of a management strategy for pancreatic cancer. ^18^FDG-PET and ^18^FDG-PET/CT were used for both the primary diagnosis and staging of pancreatic cancer in these studies, with the exception of one study, 101 which evaluated ^18^FDG-PET for staging purposes only. The management plan was altered in an important number of patients with both ^18^FDG-PET and ^18^FDG-PET/CT (up to 69 percent), more often resulting in a conservative course of management thus avoiding unnecessary surgery. ^18^FDG-PET and ^18^FDG-PET/CT may be used for the appropriate selection of surgical candidates through more accurate identification of metastases or identification of resectable disease in otherwise asymptomatic patients. One study demonstrated that ^18^FDG-PET/CT for the identification of surgical candidates would result in cost savings. 95 One study103 showed no advantage in terms of therapeutic consequences with the addition of MRI images to FDG-PET for diagnosis and staging. Only one study involving 15 patients evaluated patient-centered outcomes, 91 hence the value of FDG-PET in terms of patient-centered outcomes in pancreatic cancer remains unclear.

Table 25 provides a summary of the main findings and the types of bias that affected the evidence on the diagnostic thinking impact, effect on patient-centered outcomes of ^18^FDG-PET and ^18^FDG-PET/CT and economic outcomes for pancreatic cancer.

Table 25 Main findings and types of bias that affected the evidence on the diagnostic thinking impact, effect on patient-centered outcomes and economic outcomes of ^18^FDG-PET and ^18^FDG-PET/CT for pancreatic cancer

Study | Results of FDG-PET imaging on patient diagnosis, treatment and outcomes | Types of bias
Bang 2006^91^ Study type: Prospective | Treatment strategy and staging was impacted for 25/93 cases (27%): Upstaged: 20/25 changes Downstaged: 5/25 changes Treatment modality changed in 20/25 cases (80%): Upstaged and deemed to be unresectable: 17/20 Downstaged and deemed to be resectable: 3/20 Previously unidentified distant metastases were found in the 17 cases determined to be unresectable | Spectrum bias (unclear) Verification bias (>1 RS)
Heinrich 2005^95^ Study type: Prospective | Management decision: Treatment and diagnostic testing impact Treatment strategy changed for 6/37 patients (16%) judged to have resectable cancer. Distant metastasis detected by PET/CT only (n = 5) Simultaneous cancer found and led to change in surgery (n = 2, one with curative intent, one palliative) PET/CT enabled minimally invasive histological assessment by exact anatomic delineation of lesions Detected benign lesions in 17 patients, 10 of which were not identified by conventional CT. Some lesions required further diagnostic evaluation and no change in treatment made Economic evaluation Alternatives compared: a) Standard, routine staging; b) FDG-PET/CT + standard staging PET/CT identified metastasis and avoided surgery in 5/59 patients Total net savings from PET/CT: $62,912 ($1,066 per patient) Total net savings for patients eligible for surgery after routine staging: $105,262 ($2,844 per patient) | Spectrum bias (unclear) Selection bias (unclear) Verification bias (>1 RS) Review bias (PET, unclear; RS, unblinded)
Nishiyama 2005^101^ Study type: Prospective | Management decision: Treatment Treatment management impacted in 5/42 patients (12%) Changed from curative to palliative treatment (n = 3) Changed from palliative to curative treatment (n = 2) | Selection bias (unclear) Verification bias (>1 RS) Review bias (RS, unclear if blinded)
Ruf 2006^103^ Study type: Prospective | Management decision: Treatment and diagnostic testing impact Interpretation of PET foci improved through fusion of PET/MRI images 8/32 patients (25%) Image fusion resulted in a change of treatment in only 1 patient (surgery was expanded to curative) | Spectrum bias (unclear) Verification bias (>1 RS) Review bias (PET and RS unblinded)
Sperti 2007^105^ Study type: Prospective | Management decision: Treatment Treatment plans were altered in 44/64 patients (69%) Positive PET results impacted treatment in 10 patients Negative PET results impacted management in 34 patients | Selection bias (unclear) Disease progression bias (unclear) Verification bias (>1 RS)

CT = computed tomography; FDG = fluorodeoxyglucose F18; MRI = magnetic resonance imaging; PET = positron emission tomography; RS = reference standard

## 7 Prostate Cancer

### 7.1 Background

Cancer of the prostate is the most common cancer in men. 156 In developed countries, it is the second most frequently diagnosed cancer and the third most common cause of death from cancer in men. In 2004, the incidence of invasive prostate cancer was 145.3 per 100,000 with a death rate of 25.4 per 100,000. 157 It is estimated that 186,320 new cases will be diagnosed in the United States in 2008^133^ and there will be 28,660 attributable deaths. 133 Mortality rates in African-American men are more than twice the rates observed in other racial and ethnic groups in the United States. 158

Diagnosis of prostate cancer begins with the assessment of general health and comorbidities. 156 Prostate cancer screening is controversial because of the lack of definitive evidence of benefit. 159 The digital rectal examination (DRE) was the test traditionally used for screening; however, two other procedures, transrectal ultrasound (TRUS) imaging and serum prostate-specific antigen (PSA) concentrations are now commonly used. Imaging procedures, such as ultrasound, CT and MRI, have been suggested as possible screening modalities. Each modality has relative merits and disadvantages for distinguishing different features of prostate cancer.

The PSA test has been widely adopted in the United States in the management of prostate cancer. This test, which measures the amount of PSA protein in the blood (often elevated in patients with prostate cancer), 158 is used as a disease marker although no specific cut-off point for normal PSA has been defined. 160 This screening method can lead to overdiagnose the disease, 156,158 and the effect of early detection and treatment on mortality is not fully understood because of the long natural history of prostate cancer and the inherent delay in measurable treatment effects. 160 Bone scintigraphy may be performed if bone metastases are suspected. 156

The most common grading system used in the United States is the Gleason grading system. 161 Biopsy material is needed to assess the Gleason score. The system uses a summary score between 2 and 10 (10 being the most aggressive) of the two most common patterns of tumor growth in a biopsy specimen (one for more than 50 percent of the growth and one for the majority of the remaining tumor growth), which are each given a score of 1 to 5 (5 being the most aggressive). 160 The summary score reflects the addition of these two scores, with a higher score being indicative of more disordered growth and aggressive cancer.

Two other systems that are used for the staging of prostate cancer are the Jewett system (stages A through D) 162 and a revised TNM system that employs the same broad T stage categories as the Jewett system but includes subcategories of T stage, such as a stage to describe patients diagnosed through PSA screening. This revised TNM system is clinically useful and more precisely stratifies newly diagnosed patients. 163 Local staging (T stage) is evaluated by DRE. 156,160 Pelvic imaging using MRI or CT is performed before radical treatment when Partin tables (probabilities of disease extension and progression) indicate more than 15 percent risk of nodal involvement. 156

Rigorous evaluation of any prostate cancer screening modality is desirable because the natural history of the disease is variable and appropriate treatment is not clearly defined. 159 Clinical practice guidelines on the management of clinically localized prostate cancer demonstrate major differences in their specific recommendations, 164 and there is no general consensus as to what constitutes best treatment for localized disease. 156 Little high-quality evidence is available to guide decisions regarding the comparative effectiveness and harms of treatments for clinically localized prostate cancer, especially in men with PSA-detected disease. 165

Radical prostatectomy (removal of the entire prostate and potential removal of nearby lymph nodes), 166 radiotherapy160 and hormone therapy (androgen suppression or bicalutamide monotherapy) 156 are the main treatments for locally advanced prostate cancer. Cryosurgery is a surgical technique under development that involves destruction of prostate cancer cells by intermittent freezing of the prostate tissue with cryoprobes, followed by thawing. It is less well established than standard prostatectomy and long-term outcomes are not as well established as with prostatectomy or radiation therapy. 167

Improvements in brachytherapy have made it an effective radiotherapy for early-stage prostate cancer. Advances in hormonal therapy for prostate cancer have included the development of gonadotropin-releasing hormone (GnRH) agonists, which inhibit the ability of the pituitary gland to stimulate the testes to make testosterone. Additional approaches include bilateral orchiectomy, estrogen therapy, antiandrogens, ketoconazole, and aminoglutethimide. 159 Advances have also been made in chemotherapy for advanced prostate cancer. 158 There is high-quality evidence from one RCT in favor of surgery over watchful waiting with palliative intent for non-high grade localized prostate cancer. 168 Data from RCTs indicate that men with Gleason scores of 8 to 10 were likely to have evidence of biochemical recurrence, regardless of whether treatment was radical prostatectomy alone or was combined with androgen deprivation. High-dose electron beam radiation therapy (EBRT) was more effective than conventional-dose EBRT in controlling biochemical failure in both low-risk disease and higher-risk disease. 165

### 7.2 Importance of Key Questions in the Clinical Management of Prostate Cancer

Tumor grading of prostate cancer is a fundamental determinant of disease biology and prognosis. Implementation of an accurate noninvasive imaging technique to detect recurrent and metastatic prostate cancer is critical for the effective management of these patients. Current imaging tests in prostate cancer include ultrasound, CT, MRI, and In-111 capromab pendetide scan. There are still controversies regarding the value of ^18^FDG-PET to identify local recurrences, metastases or nodal and soft tissue lesions. ^18^FDG-PET imaging in prostate cancer can be problematic because ^18^FDG tracer undergoes renal excretion with subsequent accumulation in the urinary bladder, causing image artifacts in the lower pelvis. The close proximity of excreted ^18^FDG to sites of potential local recurrence (i.e., the prostate bed and adjacent lymph nodes) complicates the interpretation of ^18^FDG-PET images of the pelvis. Furthermore, ^18^FDG accumulation in the primary prostate cancer is generally low, and may overlap with the uptake in benign prostatic hyperplasia (BPH) and uptake in the normal gland. It is important to evaluate the utility of ^18^FDG-PET in patients with suspected or known prostate cancer, and the impact on management and patient outcomes.

### 7.3 Results

Four studies108-111 provided evidence on the use of ^18^FDG-PET or ^18^FDG-PET/CT for prostate cancer. All of them evaluated the diagnostic accuracy of ^18^FDG-PET or ^18^FDG-PET/CT. None of the studies reported on the diagnostic thinking impact of ^18^FDG-PET or ^18^FDG-PET/CT or evaluated the impact of ^18^FDG-PET or ^18^FDG-PET/CT as part of a management strategy on patient-centered outcomes. There were no economic evaluations on the use of ^18^FDG-PET and ^18^FDG-PET/CT for prostate cancer. Characteristics of the populations, conditions of ^18^FDG-PET and ^18^FDG-PET/CT administration, interpretation of results and methodological quality of the studies are summarized in Appendices D to J.

#### 7.3.1 Diagnostic accuracy of ^18^FDG-PET and ^18^FDG-PET/CT in prostate cancer

##### Characteristics of the studies

Four studies (two prospective, 109,110 two retrospective108,111) evaluated the diagnostic accuracy of ^18^FDG-PET108-111 and ^18^FDG-PET/CT111 on prostate cancer. ^18^FDG-PET was used for restaging in one study, 108 for the assessment of recurrences in one study, 110 for both restaging and recurrence purposes in two studies. 109,111 One study also used ^18^FDG-PET/CT for both staging and assessment of recurrences. 111 The studies contained a total of 173 patients with sample sizes ranging from 12 to 91 participants. Participant ages ranged from 49 to 81 years. One study reported the distribution by stage of cancer: T1N0M0 = 54 percent, T2N0M0 = 46 percent. 108 ^18^FDG-PET was compared to a reference standard that varied across the studies. In two studies the reference standard was either histology/biopsy or clinical followup, 109,111 while the reference standard in one study was either histology/biopsy or CT/bone scintigraphy. 110 One study established the final diagnosis of all patients using histology/biopsy. 108 Three studies reported the mean time between last treatment and ^18^FDG-PET as 6 months, 109 43.2 months, 111 and 3.2 years. 108 Three studies used a fixed dose of ^18^FDG (10 MCi108 and 555 MBq110,111); one study reported a dose range of 370 to 555 MBq. 109 The time between injection and PET scan was 30 to 45 minutes, 108 45 to 60 minutes, 109,111 and 40 to 90 minutes. 110 Patients fasted for four hours. 108-110 One study110 measured glucose levels before administration of ^18^FDG-PET; the maximum glucose level that was allowed was not reported. Methods of interpretation of the images were qualitative in three studies108-110 and both qualitative and quantitative in the remaining study. 111 Scans were interpreted qualitatively using visual analysis. 108-111 One study111 reported using SUV but the criterion for abnormality was not reported.

##### Comparisons

No pooled data were obtained to evaluate the accuracy of ^18^FDG-PET for prostate cancer for any of the clinical indications considered: staging, recurrences, considered together or separately (Table 26). Individual data are summarized in Appendix D.

Table 26 Summary of comparisons considered for meta-analyses of the accuracy of ^18^FDG-PET for prostate cancer

Indication | Studies | Design | Type of PET | Reference standard | Meta-analysis
Restaging and recurrences | Jadvar 2003^109^ | P | FDG-PET | Histology/biopsy or clinical followup | No
Restaging and recurrences | Schoder 2005^111^ | R | FDG-PET and FDG-PET/CT | Histology/biopsy or clinical followup | No
Recurrences | Oyama 2003^110^ | P | FDG-PET | Histology/biopsy, CT, bone scintigraphy | No
Restaging | Chang 2003^108^ | R | FDG-PET | Histology/biopsy | No

FDG = fluorodeoxyglucose F18; P = prospective; PET = positron emission tomography; R = retrospective

##### Summary of the results

Four studies of poor to moderate methodological quality evaluated the use of ^18^FDG-PET109-111 or ^18^FDG-PET/CT111 to assess both restaging and recurrences, 109,111 recurrences109-111 or restaging108 alone of prostate cancer. Due to heterogeneity across studies in terms of their design, the type of PET and indications for its use, no pooled estimate of the accuracy of ^18^FDG-PET could be obtained. The impact of ^18^FDG-PET and ^18^FDG-PET/CT on diagnostic thinking or patient-centered outcomes was not assessed in any studies. There is currently insufficient data to recommend the introduction of ^18^FDG-PET or ^18^FDG-PET/CT imaging for this indication.

## 8 Small Cell Lung Cancer

### 8.1 Background

The leading cause of cancer death world wide is lung cancer. 169 Every year 15 percent of new lung cancer diagnoses are classified as small cell lung cancer (SCLC), which accounts for up to 25 percent of lung cancer deaths. In the United States there were an estimated 213,380 new cases of lung cancer diagnosed (all types) and 160,390 deaths in 2007. 170 Rates peaked in 1986 with 17.4 percent of new cancers diagnosed as SCLC. In the early 1970s, 72.4 percent of those diagnosed with SCLC occurred in male patients. By 2002, the male to female ratio of patients diagnosed with SCLC was 1:1 in 2002. 171

Approximately 95 percent of all cases are due to cigarette smoking, although environmental factors may also play a role. Decreasing incidence and mortality rates may be related to the declining number of smokers170 (in the United States, 36 percent of population smoked in 1950 compared to 20 percent of population in 1990) 171 and the development of low-tar filters. 170 Additionally, smoking during treatment tends to shorten patient survival times. The risk of all types of lung cancer can be decreased by smoking cessation. 172

SCLC is difficult to treat due to its rapid growth and quick development of widespread metastasis. There is an initial dramatic response to treatment; however, the majority of patients die from recurrent disease. 171 Less than 5 percent of patients survive 5 years following diagnosis. 172 Disease usually reoccurs at the primary site in the lung or lymph nodes. Factors that improve prognosis are: small tumor size, no lymph node involvement and possibility of lobectomy. 173 Dyspnea, persistent cough and hemoptysis are the most common presenting symptoms and postobstructive pneumonia may also occur. Common sites of metastases include bone, liver, lymph nodes, central nervous system, adrenal glands, subcutaneous tissue and pleura. Disease that has metastasized can produce pain, headache, malaise, seizures, fatigue, anorexia and weight loss. 170 Extent of disease, performance status, gender and age are the strongest clinical prognostic factors. 172

Traditionally staging of SCLC uses a system developed by the Veterans Administration Lung Cancer Study Group (VALCSG). There are two stages, limited-stage disease (LD) and extensive-stage disease (ED). LD is defined as disease confined to one hemithorax with the tumor encompassed in one radiation port. Approximately 30 percent of patients are staged with LD at diagnosis. 170 Half of these patients achieve remission compared to the 20 to 40 percent of patients with ED. 172 ED is any cancer that does not fit into the LD category and represents patients with more disseminated disease. 170 Generally, ED patients have a poorer prognosis and palliative chemotherapy and radiation treatment aims to provide relief of symptoms with minimal toxicity. 172 The International Association for the Study of Lung Cancer has proposed TNM groupings for the clinical staging of SCLC since such systems have shown to be a good tool for predicting outcome. 174 However, TNM classifications are not typically used in SCLC as they require surgery to confirm accuracy and SCLC patients are often poor candidates for surgery.

Establishing a diagnosis of SCLC is a multi-step process that includes a detailed history, physical examination and testing involving a complete blood count, electrolyte panel and histology or cytology. 170 Contrast-enhanced CT scan of the chest and abdomen, bone scan, and CT scan or MRI of the brain are also performed. 118

PET has been used for the assessment of single pulmonary nodules and for the evaluation of the mediastinum in patients with non-SCLC. Initial studies suggest that the ^18^FDG tracer is avidly absorbed by SCLC tumors and that staging evaluation with ^18^FDG-PET may be an effective complement to conventional staging methods. 118

When treating SCLC the control of symptoms and improvements to patient quality of life should be considered. 172 In patients with LD, combination regimens of chemo and radiotherapy achieve better responses and longer survival than single agents. 170 Dosing schedules of chemo and radiotherapy may be concurrent, sequential or alternating. 169 Patients diagnosed with ED receive chemotherapy as their mainstay treatment. Patient response rate is high, at 60 to 80 percent, but the median survival time is only 8 to 10 months. 170 Palliative radiotherapy may be provided to patients with relapsed ED to help control symptoms. 172 If surgery is planned, it must be a part of a multidisciplinary approach and chemotherapy should still be considered the primary treatment. 173

### 8.2 Importance of Key Questions in the Clinical Management of Small Cell Lung Cancer

SCLC has a very aggressive biological behavior. Exact staging of SCLC has an important impact on survival and treatment decisions. The primary role of diagnostic imaging in SCLC is to accurately distinguish between LD and ED. Patients with LD are often offered concomitant chemotherapy and radiotherapy, whereas chemotherapy alone is the standard treatment of patients with ED. Thus, accurate staging is pivotal to reserve the combined modality treatment to those patients who actually might benefit from it.

Chest radiography, thorax and upper abdomen CT scan, MRI, thoracoscopy, bone scans, and bone marrow biopsy are routinely used for staging. However, the use of these diagnostic procedures may result in difficulties identifying tumor tissue in some settings (e.g., in normal-sized lymph nodes). Furthermore, anatomic imaging modalities are mostly used to evaluate a given region of the body rather than the entire body and therefore, it is likely that metastases outside the imaging field are not diagnosed. In contrast to the dependence primarily on anatomic imaging features, ^18^FDG-PET depends on the metabolic characteristics of a tissue for the detection of disease. As ^18^FDG preferentially accumulates in viable tumor cells and not in fibrotic or necrotic tissue, a change in ^18^FDG-uptake on PET scan might be a better parameter for monitoring the response and it might be able to assess response before structural changes occur.

### 8.3 Results

Ten studies112-121 provided evidence on the use of ^18^FDG-PET or ^18^FDG-PET/CT for SCLC. All of them evaluated the diagnostic accuracy of ^18^FDG-PET or ^18^FDG-PET/CT. Three studies112,113,117 reported on the diagnostic thinking impact of ^18^FDG-PET and one117 also evaluated the impact of ^18^FDG-PET/CT. None of the studies evaluated the impact of ^18^FDG-PET or ^18^FDG-PET/CT as part of a management strategy on patient-centered outcomes. There were no economic evaluations on the use of ^18^FDG-PET or ^18^FDG-PET/CT for SCLC. Characteristics of the populations, conditions of ^18^FDG-PET administration, interpretation of results and methodological quality of the studies are summarized in Appendices D to J.

#### 8.3.1 Diagnostic accuracy of ^18^FDG-PET and ^18^FDG-PET/CT in small cell lung cancer

##### Characteristics of the studies

Ten studies (six prospective, 113-118 four retrospective112,119-121) evaluated the diagnostic accuracy of ^18^FDG-PET on SCLC. Seven studies used ^18^FDG-PET for initial staging113-115,118-121 and three used ^18^FDG-PET for both initial staging and restaging. 112,116,117 The studies contained a total of 471 patients with sample sizes ranging from 21 to 120 participants. Participant ages ranged from 33 to 90 years. ^18^FDG-PET was compared to a reference standard that varied across the studies. In four studies the reference standard was either histology/biopsy or clinical followup, 112,113,117,120 three studies used clinical followup and conventional imaging. 116,119,121 One study established the final diagnosis by histology/biopsy and conventional imaging, 114 one study used histology/biopsy, 115 and one study used conventional imaging. 118 Two studies reported the median time between last treatment and ^18^FDG-PET as 207 days120 and 4 days; 119 one reported the time as greater than two weeks. 118 Five studies used a fixed dose of ^18^FDG (400MBq, 115,116 370MBq, 120 300MBq, 119 and 15MCi118); three used a dose range (300 to 400MBq, 117 10 to 15MCi, 113 and 15 to 20MCi121); one used a weight-based dose (5MBq/kg114); and one did not report on dosing. 112 The time between ^18^FDG injection and PET scan was 50 minutes, 113 60 minutes, 115,118-120 a median of 84 minutes, 116 90 minutes, 114 and two studies reported ranges (45 to 60 minutes121 and 50 to 60 minutes117). In nine studies patient fasting was reported between four and twelve hours, 112-120 with five of these studies measuring maximum glucose levels before administration of ^18^FDG-PET (4.6 mmol/L, 116 4.7 mmol/L, 115 6 mmol/L, 114 and 150 mg/dL113,118). Methods of interpretation were qualitative in four studies114,115,118,119 and both qualitative and quantitative in four studies. 112,113,116,120 Scans were interpreted qualitatively using visual analysis in all eight studies. One study112 used a marker of lesions greater than 10 mm in transverse diameter for quantitative interpretation of the PET images.

##### Comparisons

Comparisons for which data were considered for direct meta-analysis are summarized in Table 27. Statistical pooling was considered to evaluate the accuracy of ^18^FDG-PET and ^18^FDG-PET/CT for the staging of SCLC. Individual study data are summarized in Appendix D.

Table 27 Summary of comparisons considered for meta-analyses of the accuracy of ^18^FDG-PET for SCLC

Indication | Studies | Design | Type of PET | Reference standard | Meta-analysis
Staging and restaging | Blum 2004^112^ | R | FDG-PET | Histology/biopsy or clinical followup | No
Staging and restaging | Fischer 2006^116^ | P | FDG-PET/CT | Clinical followup | No
Staging and restaging | Kamel 2003^117^ | P | FDG-PET and FDG-PET/CT | Histology/biopsy or clinical followup | No
Staging | Bradley 2004^113^ | P | FDG-PET | Histology/biopsy or clinical followup | 1. FDG-PET v. all comparators (P studies)113,114,118 2. FDG-PET or FDG-PET/CT v. all comparators (R studies) 119,121
Staging | Brink 2004^114^ | P | FDG-PET | Histology/biopsy or conventional staging | 1. FDG-PET v. all comparators (P studies)113,114,118 2. FDG-PET or FDG-PET/CT v. all comparators (R studies) 119,121
Staging | Fischer 2007^115^ | P | FDG-PET and FDG-PET/CT | Histology/biopsy | 1. FDG-PET v. all comparators (P studies)113,114,118 2. FDG-PET or FDG-PET/CT v. all comparators (R studies) 119,121
Staging | Kut 2007^118^ | P | FDG-PET | Conventional staging | 1. FDG-PET v. all comparators (P studies)113,114,118 2. FDG-PET or FDG-PET/CT v. all comparators (R studies) 119,121
Staging | Niho 2007^119^ | R | FDG-PET and FDG-PET/CT | Clinical followup or conventional staging | 1. FDG-PET v. all comparators (P studies)113,114,118 2. FDG-PET or FDG-PET/CT v. all comparators (R studies) 119,121
Staging | Pandit 2003^120^ | R | FDG-PET | Histology/biopsy or clinical followup | 1. FDG-PET v. all comparators (P studies)113,114,118 2. FDG-PET or FDG-PET/CT v. all comparators (R studies) 119,121
Staging | Vinjamuri 2008^121^ | R | FDG-PET and FDG-PET/CT | Clinical followup | 1. FDG-PET v. all comparators (P studies)113,114,118 2. FDG-PET or FDG-PET/CT v. all comparators (R studies) 119,121

FDG = fluorodeoxyglucose F18; P = prospective; PET = positron emission tomography; R = retrospective

###### 1 ^18^FDG-PET for the staging of SCLC

Reference standard: any; prospective studies. Three prospective studies113,114,118 totaling 162 participants provided data to analyze the accuracy of ^18^FDG-PET v. any reference standard for identifying the stage of SCLC. Individual 2x2 table results are presented in Figure 83. Sensitivity in the three studies was 100 percent. The studies did not provide data to calculate specificity and therefore, pooled estimates of the positive and negative LRs were not obtained.

Figure 83 Results from 2x2 tables of individual prospective studies of ^18^FDG-PET v. any reference standard for the staging of SCLC

###### 2 ^18^FDG-PET/CT for the staging of SCLC

Reference standard: any; retrospective studies. Two retrospective studies119,121 totaling 114 participants provided data to analyze the accuracy of ^18^FDG-PET/CT v. any reference standard for identifying the stage of SCLC. Individual 2x2 table results are presented in Figure 84. Sensitivity was 100% in the two studies. 119,121 The specificity was 0.98 in one study, 119 however the second study did not provide data to calculate specificity and therefore, pooled estimates of the positive and negative LRs were not obtained.

Figure 84 Results from 2x2 tables of individual retrospective studies of ^18^FDG-PET/CT v. any reference standard for the staging of SCLC (retrospective studies)

##### Summary of the results

No conclusions can be drawn regarding the utility of ^18^FDG-PET or ^18^FDG-PET/CT for the staging of SCLC. No pooled estimates of the positive and negative LRs were obtained. Information about the specificity of the test is not available from the studies included in this analysis.

#### 8.3.2 Diagnostic thinking impact of ^18^FDG-PET and ^18^FDG-PET/CT on physician decision making with respect to diagnosis and management strategy for patients with small cell lung cancer

Three studies reported on the diagnostic thinking impact of ^18^FDG-PET. Blum et al. 112 evaluated the treatment decision impact of ^18^FDG-PET on staging and restaging patients with SCLC. Thirty-six consecutive outpatients who had undergone 47 ^18^FDG-PET scans were retrospectively enrolled in this study. Of the 36 patients, 15 underwent ^18^FDG-PET for staging and 25 for restaging, of which four patients had previously undergone staging. The treatment plan was considerably altered for 17 (43 percent) of all cases. Seven of the 15 (47 percent) patients who underwent ^18^FDG-PET for initial staging had changes to their treatment plans due to upstaging in their disease identified by ^18^FDG-PET. Five of these patients had their management altered from radical concurrent chemoradiotherapy to palliative chemotherapy alone or the later addition of palliative radiotherapy. The remaining two patients had their radiotherapy target volume changed to include additional disease shown by ^18^FDG-PET. In addition, 10 of the 25 patients (40 percent) who underwent ^18^FDG-PET for restaging had their treatment plans changed. Five of these patients were upstaged based on ^18^FDG-PET and therefore avoided prophylactic cranial irradiation (PCI) (n = 3) or changed from chemotherapy to observation alone (n = 2). Three patients were downstaged and went on to have PCI. An additional two patients were reported to have changes in their treatment plan but the nature of this change was not described.

Prognostic outcomes were also reported in the study. Patients who achieved a complete metabolic response on ^18^FDG-PET had a median time to progression of 13.7 months, compared to 9.7 months for patients who did not achieve a complete response. In addition, of the 16 patients with an incomplete response, five were still alive with a median followup of 19 months. It is possible that salvage treatments had a favorable impact on patients found to have residual disease by ^18^FDG-PET.

The authors concluded that ^18^FDG-PET could be used in conjunction with conventional imaging to improve staging and better ensure that patients receive the most appropriate management.

This retrospective study reviewed consecutive patients and was assessed to be of moderate quality. The spectrum of included patients, the choice of reference standard, any intermediate results and withdrawals were well reported. Although all patients received a reference standard, the reference standards were not the same across all patients; some received histological confirmation of disease and others were followed up clinically. The multiple methods used to validate disease status may have lead to verification bias. In addition, the selection criteria and execution of the index and reference tests were only partially described and the duration between the index and reference tests was unclear. The results of the index test were interpreted in an unblinded manner and the blinding of the reference test interpretation was unclear.

Bradley et al. 113 evaluated the treatment decision impact of ^18^FDG-PET on the staging of SCLC. A prospective sample of 25 outpatients with newly diagnosed, untreated, histologically or cytologically confirmed SCLC underwent ^18^FDG-PET scans. Of these, 24 were included in the analysis and one patient withdrew from the study. ^18^FDG-PET scans contributed to a change in the diagnosis of seven patients (29 percent), all of whom were upstaged. An unsuspected primary tumor or regional nodal metastasis was identified by ^18^FDG-PET in seven patients (29 percent), six of whom had nodes that were not considered enlarged by CT criteria but showed ^18^FDG uptake on PET. This resulted in a significant alteration to the radiation therapy portal and the nodes were included in the high-dose region for each of these patients. Further, the addition of ^18^FDG-PET identified two patients (8 percent) with ED SCLC who were thought to have LD based on conventional staging.

The authors concluded that ^18^FDG-PET had high sensitivity and appeared to be of value for staging and treatment planning in patients presumed to have LD SCLC.

This study was determined to be of high quality. The selection criteria, choice of the reference standard, intermediate test results and study withdrawals were well reported. In addition, the reference standard was independent of the index test and all the tests were conducted within a sufficiently brief time period. However, reporting of the recruitment of patients was inadequate and the execution of the index and reference tests. Since cases were not all verified using the same reference standard, there is risk of verification bias. Although the reference standard was interpreted while blinded to the results of the ^18^FDG-PET, the results of the reference tests were used in the interpretation of the ^18^FDG-PET scans, which raises the possibility of review bias.

Kamel et al. 117 investigated the treatment decision impact of ^18^FDG-PET and integrated ^18^FDG-PET/CT on staging and restaging in patients with SCLC. Forty-five consecutive outpatients who underwent ^18^FDG-PET imaging were retrospectively enrolled in the study; however, three patients were excluded due to incomplete data, therefore 42 patients were included in the analysis. Of these, 24 patients were referred for ^18^FDG-PET for initial staging and 20 for restaging, where two patients were included for both staging and restaging. No description regarding the interpretation of the scans was provided. The treatment management was altered in 12 of 42 patients (29 percent). Nine patients with ^18^FDG-PET for initial staging had a change in treatment; three were given palliative chemotherapy and one patient was given curative surgery since ^18^FDG-PET findings excluded mediastinal involvement and distant metastases. Three patients had a change in radiation field and two patients had a change in radiation volume. Therefore, of the patients who received ^18^FDG-PET for initial staging, three were upstaged, one was downstaged and five had minor changes to their diagnosis which influenced their treatment plan. Three of the 20 patients (15 percent) with ^18^FDG-PET for restaging after therapy had a change in treatment management; one patient had chemotherapy reinstituted, while chemotherapy was discontinued in two patients. Four patients had a change in diagnosis, including the three patients with changes in regards to chemotherapy and one patient with a false negative from ^18^FDG-PET. Three additional patients were identified as having progressive disease by ^18^FDG-PET and therefore had a minor change to their diagnosis that did not impact their treatment.

The authors concluded that ^18^FDG-PET imaging has the potential to improve the outcomes of combined chemoradiotherapy by preventing futile treatment of patients with distant metastases or advanced locoregional disease not identified by conventional imaging. In addition, ^18^FDG-PET may optimize radiation treatment for patients with LD through its accurate definition of radiation field and volume.

This retrospective study of consecutive patients was assessed to be of high quality. The spectrum of included patients, the execution of the index test, intermediate results and study withdrawals were well reported. In addition, patients received an appropriate reference standard, which was consistent across all patients. Although there was blinded interpretation of the reference standard, the index test was interpreted with knowledge of the results of the standard, introducing risk of review bias. Other weaknesses of this study included only partial description of the selection criteria, raising the possibility that the results are not generalizable to other patient populations. In addition, disease progression bias cannot be ruled out as there was lack of clarity with regard to the time between the diagnostic tests. Finally, results were not presented separately for ^18^FDG-PET and ^18^FDG-PET/CT.

##### Summary of the results

There is some evidence from three studies of moderate to high quality that ^18^FDG-PET112,113,117 or ^18^FDG-PET/CT117 is useful in the staging of SCLC resulting in more appropriate management and in cases of upstaging avoidance of ‘futile’ therapy. The studies consistently demonstrated that ^18^FDG-PET altered management plans in an important proportion of patients. The change in management varied, but patients were more frequently upstaged, resulting in more aggressive treatment or switching to palliative care. One study112 examined prognostic outcomes and found that complete metabolic responders on ^18^FDG-PET had a median time to progression of 13.7 months, compared to 9.7 months for patients who did not achieve a complete response.

Table 28 provides a summary of the main findings and the types of bias that affected the evidence on the diagnostic thinking impact and effect on patient-centered outcomes of ^18^FDG-PET and ^18^FDG-PET/CT for SCLC.

Table 28 Main findings and types of bias that affected the evidence on the diagnostic thinking impact of ^18^FDG-PET and ^18^FDG-PET/CT for SCLC

Study | Results of FDG-PET imaging on patient diagnosis and treatment | Types of bias
Blum 2004^112^ Study type: Retrospective | Management decision: Treatment Treatment plans altered for 17/36 patients (47%) overall Initial staging: 7/15 plans changed (all upstage) Radical concurrent chemotherapy to palliative therapy (n = 5) Radiotherapy target volume increased (n = 2) Restaging: 10/25 plans changed (3 upstage, 5 downstage, 2 ND) PCI in patients with positive CT but negative FDG uptake (n = 3) PCI omitted in cases that did not have complete response (n = 3) Observation in cases with no FDG uptake but positive CT (n = 2) Prognostic outcomes: Complete metabolic responders on PET had a longer median time to progression (13.7 mo v. 9.7 mo) | Selection bias (unclear) Disease progression bias (unclear) Verification bias (>1 RS) Review bias (PET unblinded; RS, unclear)
Bradley 2004^113^ Study type: Prospective | Management decision: Treatment Major change in diagnosis of 7/25 patients (28%); all upstaged Among these, unsuspected primary tumor identified in 6 patients (not detected by CT), leading to significant change to radiation therapy portal Identification of 2 patients with extensive-stage disease, who were diagnosed as limited-stage SCLC by conventional staging | Spectrum bias (unclear) Selection bias (unclear) Verification bias (>1 RS) Review bias (RS, unclear if blinded)
Kamel 2003^117^ Study type: Retrospective | Management decision: Treatment Treatment altered in 12/42 patients (29%) overall. Initial staging: 9/24 changes in management. Upstaged and palliative chemotherapy (n = 3); downstaged and curative resection (n = 1); minor change to diagnosis and altered radiation field (n = 5) Restaging after therapy, 3/20 changes in management: chemotherapy reinstituted (n = 1); discontinued (n = 2) | Selection bias (unclear) Disease progression bias Review bias (PET and RS unblinded)

CT = computed tomography; FDG = fluorodeoxyglucose F18; ND = no data; PET = positron emission tomography; RS = reference standard

## 9 Testicular Cancer

### 9.1 Background

Testicular cancer is characterized by malignant cells in one or both testicles. The majority (95 percent) of testicular neoplasms are germ cell tumors (GCTs) with other neoplasms, such as sex-chord stromal tumors and lymphomas occurring only rarely. 175 GCTs are broadly separated into two groups: seminomas and nonseminomas, each comprising approximately 50 percent of cases. 175 Seminomas originate from the sperm-producing germ cells of the testes and may be one of three types: classic, anaplastic, or spermatocytic. Nonseminomas are also germ cell tumors but appear very different histologically. Types of nonseminomas include choriocarcinoma, embryonal carcinoma, teratoma, and yolk sac tumors. Testicular tumors may contain both seminoma and nonseminoma cells. 176

Testicular cancer is the most common cancer in men between the ages of 15 and 35 years, accounting for one to two percent of all neoplasms in men. 177 In 2004, the incidence of invasive testicular cancer was 5.2 per 100,000 and the attributable death rate 0.2 per 100,000 (measures adjusted by age to the 2000 United States standard population). 157 National cancer statistics estimate that there will be 8,090 new cases and 380 deaths in 2008. 133 Testicular cancer occurs most often in men between the ages of 20 and 39. 176

Testicular changes symptomatic of GCT are usually found during self-examination, after testicular trauma or by a sex partner. 177 Signs and symptoms of testicular cancer include acute pain in the testicle or scrotum, dull ache in the scrotum or abdomen, scrotal heaviness, and firmness of the testicle. A physical examination includes palpation of the testes and is accompanied by blood tests that measure the levels of tumor markers178 such as alpha-fetoprotein (AFP), beta-human chorionic gonadotropin (ß-HCG), and lactate dehydrogenase (LDH). Higher than normal levels of these markers may suggest the presence of a testicular tumor, even if it is too small to be detected by physical exams or imaging tests. 176 Scrotal ultrasonography determines whether a suspected mass is intra- or extratesticular. Intratesticular masses are presumed to be cancerous until proven otherwise. 177 Final diagnosis is often made by radical orchiectomy (surgical removal of the testicle through an incision in the groin). PET scans are not yet recommended outside clinical trials as part of routine staging procedures because the procedure has not conclusively demonstrated improved sensitivity of staging compared with CT scanning alone. 178

After testicular cancer is diagnosed, a patient may receive CT of the abdomen and pelvis to detect metastasis to the retroperitoneal lymph nodes and chest radiography. 177 Patients with neurologic symptoms may receive CT or MRI of the brain. 177

Testicular cancer is categorized using the TNMS system. Staging is determined based on how much the primary tumor has spread to tissues surrounding the testicles, on extent of spread to regional lymph nodes, on metastasis to other organs, and on serum levels of proteins produced by certain types of testicular cancer. 177

With overall cure rates of more than 95 percent (80 percent for metastatic disease), testicular GCT are considered the model for curable cancer. 175 Nonseminomas tend to grow and spread more quickly; seminomas are more sensitive to radiation. As a result, treatment options differ slightly depending on the characterization of the cancer. If the tumor contains both seminoma and nonseminoma cells, it is treated as a nonseminoma. 176

The primary treatment for all testicular tumors is radical inguinal orchiectomy. 177,178 Almost all seminomas are curable with orchiectomy with or without radiation, and only occasionally do these cancers require chemotherapy. 175 Nonseminomatous GCTs are less sensitive to radiation and, when metastatic, frequently require both chemotherapy and surgery. 175 A surveillance strategy is an option for patients with stage I seminomas, 178 radiation therapy for seminomas stage I and IIa, and lymph node dissection for stage I and II nonseminoma. 177 Though limited data exist to guide the choice of high-dose (2-3 cycles of etoposide and carboplatin with or without cyclophosphamide or ifosfamide) or conventional-dose chemotherapy for initial salvage treatment, 175 chemotherapy is a treatment option for seminoma stage II and III and all stage II nonseminoma. 177

Multiple studies have demonstrated the importance of resecting residual masses following first-line of salvage chemotherapy for nonseminoma GCTs. 175 Postchemotherapy surgical resection of seminoma is technically more difficult and carries a higher morbidity due to the desmoplastic reaction frequently induced by treatment. 175 PET scan can be used to guide surgical decisions in this setting. 175

### 9.2 Importance of Key Questions in the Clinical Management of Testicular Cancer

The role of ^18^FDG-PET in the diagnosis, staging and followup of germ cell tumors is still a matter of debate and there is a need to define optimal indications for ^18^FDG-PET in testicular cancer. ^18^FDG-PET may have a role in distinguishing between benign and malignant tissue by characterizing the metabolic activity of the tissue rather than the anatomical size only. ^18^FDG-PET may also offer the potential to detect residual malignancy after primary curative therapy for testicular cancer. For many solid tumors the early detection of recurrent or residual disease may not confer a clinical benefit to patients, because further curative treatment options may not be available. However, residual or recurrent germ cell malignancy can be cured by further treatment and hence ^18^FDG-PET may have an important clinical role for patients with such tumors. Existing imaging methods, such as CT scan, chest X-ray and tumor marker evaluation with AFP and β-HCG may be insufficient to identify absent, residual or recurrent disease. Identification of these characteristics may influence subsequent patient management policy

### 9.3 Results

Four studies122-125 provided evidence on the use of ^18^FDG-PET for testicular cancer. We did not find studies that reported on the use of ^18^FDG-PET/CT for testicular cancer. All the four studies122-125 evaluated the diagnostic accuracy of ^18^FDG-PET, one study124 reported on the diagnostic thinking impact of ^18^FDG-PET. None of the studies evaluated the effects of ^18^FDG-PET or ^18^FDG-PET/CT as part of a management strategy on patient centered outcomes. There were no economic evaluations on the use of ^18^FDG-PET or ^18^FDG-PET/CT for testicular cancer. Characteristics of the populations, conditions of ^18^FDG-PET administration, interpretation of results and methodological quality of the studies are summarized in Appendices D to J.

#### 9.3.1 Diagnostic accuracy of ^18^FDG-PET and ^18^FDG-PET/CT in testicular cancer

##### Characteristics of the studies

Four studies (three prospective, 122,123,125 one retrospective124) evaluated the diagnostic accuracy of ^18^FDG-PET on testicular cancer. One study used ^18^FDG-PET for initial staging, 125 one for restaging purposes, 122 and two to assess recurrences. 123,124 The studies contained a total of 135 patients with sample sizes ranging from 15 to 54 participants. Participant ages ranged from 20 to 62 years. Two studies reported the distribution by clinical stage of cancer. One included patients at CS I (20 percent), CS II (47 percent) and CS III (33 percent); 124 the other included patients at CS IIb (10 percent), CS IIc (70 percent) and CS III (20 percent). 123 ^18^FDG-PET was compared to a reference standard that varied across the studies. In two studies the reference standard was either histology/biopsy or clinical followup. 122,125 One study established the final diagnosis of all patients using histology/biopsy123 and one study used clinical followup for final diagnosis. 124 Two studies reported the median time between last treatment and ^18^FDG-PET as 29 days123 and 45 days; 124 one reported the time since last treatment as 4 to 12 weeks. 122 All studies used a fixed dose of ^18^FDG, which ranged from 320 MBq to 400 MBq. When reported, the time between injection and PET scan was 45 minutes. 122,125 Patients fasted for four hours122,123 to six hours. 124,125 Two studies122,123 measured glucose levels before administration of ^18^FDG-PET; the maximum glucose level that was allowed was normal levels. Methods of interpretation of the images were qualitative in three studies122,124,125 and both qualitative and quantitative in one. 123 Scans were interpreted qualitatively using visual analysis in all studies. SUV values were reported in one study123 for interpretation of the PET images. The criterion for abnormality was SUV greater than 2 g/mL.

##### Comparisons

No pooled data were obtained to evaluate the accuracy of ^18^FDG-PET for testicular cancer for any of the clinical indications considered (i.e., staging, recurrences, and restaging) (Table 29). Individual data are summarized in Appendix D.

Table 29 Summary of comparisons considered for meta-analyses of the accuracy of ^18^FDG-PET for testicular cancer

Indication | Studies | Design | Type of PET | Reference standard | Meta-analysis
Staging | Lassen 2003^125^ | P | FDG-PET | Histology/biopsy or clinical followup | No
Recurrences | Hinz 2008^123^ | P | FDG-PET | Histology/biopsy | No
Recurrences | Karapetis 2003^124^ | R | FDG-PET | Clinical followup | No
Restaging | Becherer 2005^122^ | P | FDG-PET | Histology/biopsy or clinical followup | No

FDG = fluorodeoxyglucose F18; P = prospective; PET = positron emission tomography; R = retrospective

##### Summary of the results

Four studies of moderate methodological quality evaluated the diagnostic accuracy of ^18^FDG-PET122-125 in the staging, 125 restaging, 122 or recurrence123,124 of testicular cancer. Due to heterogeneity in the study designs and indications for which ^18^FDG-PET was used, no pooled estimate of the diagnostic test performance could be obtained.

#### 9.3.2 Diagnostic thinking impact of ^18^FDG-PET on physician decision making with respect to diagnosis and management strategy for patients with testicular cancer

One study124 reported on the diagnostic thinking impact of ^18^FDG-PET. The retrospective study by Karapetis et al. 124 examined the treatment decision impact of ^18^FDG-PET imaging on assessing the recurrence of testicular cancer. A series of 15 patients with metastatic or extragonadal germ cell tumors, who had undergone ^18^FDG-PET scanning were enrolled. The treatment plan was altered in only one patient on the basis of the ^18^FDG-PET scan; management was changed from observation to surgical excision of residual mass. Normal ^18^FDG-PET scans provided confirmation in four patients with small residual masses; however, did not alter their subsequent treatment. Seven patients had more than one ^18^FDG-PET scan. The subsequent ^18^FDG-PET scans supported, but did not change, treatment management plans.

The authors concluded that ^18^FDG-PET scanning did not have a discernable impact on treatment decisions for the majority of patients. However, ^18^FDG-PET often provided support for management decisions made on the basis of the results of other clinical assessments. The authors recommended that ^18^FDG-PET scans should be arranged with a clear aim in patient management and should not be interpreted in isolation of other assessments.

This study was assessed to be of moderate quality. The spectrum of patients included was representative of patients who would receive the test in practice, a reference standard was applied to the whole sample and was independent of the index test, and all patients and test results were accounted for. However, both the choice of reference standard and time period between tests was unclear. The selection criteria were only partially described, raising the possibility of selection bias. The authors acknowledge the risk of selection bias that is inherent to this study, particularly relevant given the retrospective nature of data collection. In addition, patients did not all receive the same reference standard test and the execution of the index and reference tests was not described sufficiently. Although the index test was blindly interpreted, the reference standard was interpreted using the results of the index, which may have introduced review bias.

##### Summary of the results

The evidence for ^18^FDG-PET in testicular cancer is very limited and inconclusive. One small retrospective study124 of moderate methodological quality evaluated the physician decision-making impact when ^18^FDG-PET imaging is used in the assessment of the recurrence of testicular cancer. The management plan was changed in only a small proportion of the patients. Small residual masses were confirmed in 27% (4/15) of patients; however had no effect on subsequent treatment decisions. Evidence from larger, prospective studies of higher quality is needed before conclusions can be made regarding the impact of ^18^FDG-PET imaging on patient management for testicular caner.

Table 30 provides a summary of the main findings and the types of bias that affected the evidence on the diagnostic thinking impact of ^18^FDG-PET for testicular cancer.

Table 30 Main findings and types of bias that affected the evidence on the diagnostic thinking impact of ^18^FDG-PET for testicular cancer

Study | Results of FDG-PET imaging on patient diagnosis and treatment | Types of bias
Karapetis 2003^124^ Study type: Retrospective | Management decision: Treatment Management plan altered in only 1/15 patients (7%) Changed from observation to surgical excisions of residual Confirmation of small residual masses in 4/15, subsequent treatment not altered | Selection bias (unclear) Disease progression bias (unclear) Verification bias (>1 RS) Review bias (RS unblinded)

FDG = fluorodeoxyglucose F18; PET = positron emission tomography; RS = reference standard