# Methods

## Overview

In this chapter, we document a prospectively designed protocol that the U of A EPC followed for this technology assessment report on the use of ^18^FDG-PET and ^18^FDG-PET/CT for nine cancers.

To accomplish the tasks as directed, a core research team composed of clinical investigators and methodologists was assembled. The core research team was trained and experienced in systematic review methodology or critical appraisal of the scientific literature in diagnostic tests.

In this chapter, we describe the technology assessment methods. We outline our inclusion and exclusion criteria, the study selection process for identifying relevant articles, and the process for abstracting information from eligible studies. Finally, we describe the methods for assessing the methodological quality of individual studies, the analysis and synthesis of the results.

## Literature Search and Retrieval

Comprehensive searches of four biomedical electronic databases (Table 2) were conducted for the time periods specified. All search strategies were developed by a research librarian with input from the project team. The search strategy comprised both controlled vocabulary and keywords. Separate searches were done for each cancer. The search was not restricted by language and articles were retrieved from 2003 to the present. No study design filters were used since the research questions could be answered by a large variety of study types. See Appendix A for detailed search strings.

Table 2 Databases Searched for Relevant Studies

Database | Years/issues | Date of search
MEDLINE^®^ | 2003 - 2008 | 12 March, 2008
EMBASE | 2003 - 2008 | 12 March, 2008
CENTRAL (Cochrane Central Register of Controlled Trials, NHS Economic Evaluation Database) | 1st Quarter 2008 | 20 March, 2008
Scopus | 2003 - 2008 | 19 March, 2008

## Criteria for Selection of Studies

A set of inclusion and exclusion criteria was used to determine eligibility of studies for the technology assessment (Table 3). Briefly, eligible studies were published in English and evaluated the use of ^18^FDG-PET or ^18^FDG-PET/CT in a sample of 12 or more adult participants (older than 16 years of age) with primary cancer of the following type: bladder, brain, cervical, kidney, ovarian, pancreatic, prostate, small cell lung, and testicular. Restrictions in terms of study design were not imposed and both prospective and retrospective studies were included.

Table 3 Inclusion Criteria

Category | Criteria
Source | - English language studies reporting original research from 2003 to March 2008;; - Study not duplicated or superseded by later study with the same purpose from the same institution
Population | - Studies ≥12 human participants;; - The study provides separate data for a population consisting of adults (>16 years) with primary cancer of the following type: bladder, brain, cervical, kidney, ovarian, pancreatic, prostate, small cell lung, and testicular
Test | - Studies of PET or PET/CT using ^18^FDG as radioisotope tracer
Comparator | - ^18^FDG-PET or ^18^FDG-PET/CT should be compared to a reference standard, where either: a) all participants undergo both ^18^FDG-PET or ^18^FGD-PET/CT and the reference standard; or b) one group of patients undergo ^18^FDG-PET or ^18^FGD-PET/CT and the other undergo the reference standard; - Examples of possible reference standard: MRI, CT, biopsy/histology, X-rays, ultrasound, PET with other radioisotope tracer, clinical followup
Study design | - Prospective or retrospective studies
Outcomes of interest | - Study should provide numeric data for the outcomes of interest in the review

CT = computed tomography; ^18^FDG = fluorodeoxyglucose; MRI = magnetic resonance imaging; PET = positron emission tomography

Studies must have reported numeric data on at least one outcome of interest for the key questions of the technology assessment. A study can contribute with data for more than one of the questions addressed in the technology report. For studies on the diagnostic performance of ^18^FDG-PET and ^18^FDG-PET/CT (Q1), the outcomes of interest were: sensitivity, specificity, positive and negative predictive values, and LR. Other outcomes that were examined for Q2, Q3 and Q4 included:

- additional diagnostic test work-up;
- treatment decisions and management strategy;
- changes in therapy;
- patient-centered outcomes (e.g., survival, quality of life, prognostic indicators, time until recurrence); and
- economic outcomes.

## Study Selection Process

### Screening of titles and abstracts

One of four reviewers evaluated the title and abstract of each study to select references potentially relevant to the topics of the report (Appendix B). The full-text of studies meeting the criteria was retrieved as was the full-text of those that reported insufficient information to determine eligibility.

### Identification of studies eligible for the report

Two independent reviewers appraised the full-text of potentially relevant articles using a standard form (Appendix B). Disagreements about the inclusion or exclusion of studies were resolved by consensus among reviewers.

## Evaluating the Methodological Quality of Studies and Grading the Evidence

The methodological quality of studies that assessed the diagnostic performance (Q1) and the diagnostic thinking impact (Q2) of ^18^FDG-PET and ^18^FDG-PET/CT was assessed using the Scottish Intercollegiate Guidelines Network (SIGN) assessment tool for diagnostic studies, 17 which is based on the Quality Assessment of Studies of Diagnostic Accuracy (QUADAS) tool. 18 Studies assessing the impact of ^18^FDG-PET and ^18^FDG-PET/CT as part of a management strategy to improve patient-centered outcomes (Q3) are different from diagnostic performance studies and would be more akin to standard effectiveness studies (e.g., clinical trials, observational analytical cohort studies). Therefore, an individual components approach that considered important aspects of design, conduct, and reporting of effectiveness studies was used to assess the methodological quality of Q3 studies. Finally, the methodological quality of economic evaluations of ^18^FDG-PET and ^18^FDG-PET/CT was assessed using the Consensus on Health Economic Criteria (CHEC). 11 See Appendix B for the quality assessment instruments used in this technology report.

Evidence from the selected studies was graded using a system adopted by the Veterans Affairs Technology Assessment Program (VATAP) to classify the level of evidence regarding the clinical utility of studies on PET (Table 4).

Table 4 Grading Scheme for Diagnostic Studies

Grade | Criteria
A | Prospective studies with broad generalizability to a variety of patients and no significant flaws in research methods.
B | Prospective studies with a narrower spectrum of generalizability, and with only a few flaws that are well described (and impact on conclusions can be assessed).
C | Studies with several methods flaws (e.g., small sample size and retrospective)
D | Studies with multiple flaws in methods (e.g., no credible reference standard for diagnosis)

Adapted from Robert et al. 1999^1^

Two reviewers assessed the methodological quality of studies independently. Disagreements were resolved by consensus or, when no consensus could be reached, a senior methodologist adjudicated.

## Data Collection

Information regarding the study design and methods, characteristics of participants, PET and comparison tests, and outcomes of interest were extracted using a pretested data extraction form that was adapted to each of the four key questions (Appendix B).

General data relevant to the review were collected on a general data extraction form. This included information on the country, year and type of publication, study design, setting, duration of the study, and number of participating centers. Data on characteristics of study participants included type of primary cancer, how participants were enrolled, inclusion and exclusion criteria, demographic characteristics, and stage or severity of their condition.

Data on characteristics of ^18^FDG-PET and ^18^FDG-PET/CT included a description of the purpose of their use within the study, technical details of the devices and administration procedures, and characteristics of the reference tests. Likewise, information on the criteria for interpretation was extracted. Specific forms were used to collect data for each of the four key questions of the report. Finally, information was collected on study conclusions, as reported by the authors of the primary studies. Data from the primary studies were extracted by one reviewer and then independently verified for accuracy and completeness by a second reviewer. Any discrepancies in data extraction were resolved by consensus between the data extractor and the data verifier. Study selection, methodological quality assessment, and data extraction were managed with Microsoft Excel™ (Microsoft Corporation, Redmond, WA). Extraction of data from graphs was performed using Corel Draw^®^, version 9.0 (Vector Capital, San Francisco, CA).

## Evidence Synthesis

Characteristics of the included studies were summarized using descriptive statistics (i.e., proportions and percentages for categorical data; means with standard deviations [SD], or medians with interquartile ranges [IQR], for continuous data).

Data were analyzed qualitatively. Evidence tables were constructed to report information on each article’s source, study design, study population, characteristics of ^18^FDG-PET and ^18^FDG-PET/CT and reference tests, and outcomes. The evidence tables also included summaries of study quality and comments to help interpret the outcomes. Data were combined by type of cancer to provide summary information across studies for each of the key questions, if appropriate.

For each of the four key questions, the following study characteristics were summarized and discussed:

a. Inclusion criteria of studies (patients and disease characteristics)
b. PET technology used (^18^FDG-PET alone, ^18^FDG-PET/CT) and comparator
c. Tests used prior to, concurrent with or after the PET scanning and whether the studies indicated the information contributed by PET beyond that provided by other tests
d. Overall quality of the body of evidence
e. The generalizability of the summarized evidence to the Medicare population (aged >65 years)
f. The generalizability of the summarized evidence to other cancers
g. Homogeneity of SUVs with respect to ^18^FDG dose, timing of study, and scanner variability

For the question related to ^18^FDG-PET and ^18^FDG-PET/CT diagnostic test performance, two-by-two tables (or two-by-one if only reference standard positive or reference standard negative subjects were included) were constructed for each comparison test or combination of tests within the individual studies. Sensitivity and specificity were calculated for each study using standard formulas. Results were graphed in forest plots for visual analysis, but were not pooled statistically due to the different diagnostic thresholds of the various studies. Individual study results were grouped when two or more studies assessed the same type of PET (i.e., ^18^FDG-PET or ^18^FDG-PET/CT) for similar purposes (e.g., primary diagnosis, staging, restaging, recurrences), had similar study design (i.e., prospective or retrospective), and had usable data for common outcomes of interest. Studies using different methods to confirm the final diagnosis were considered for grouping, but results were also presented separately by type of reference standard.

Summary estimates of the LR, both positive and negative, were meta-analyzed using the DerSimonian and Laird random effects method. 19 The LRs are a measure of the performance of diagnostic tests, expressing the magnitude by which the odds of a diagnosis in a given patient is modified by the result of a test. 20 For example, if an individual has probability of disease of 0.1 prior to taking a test (odds = 0.09) and the test has a positive LR of 4 and a negative LR of 0.2, the patients’ post test odds of having the disease would be 4*0.09 = 0.36 (probability = 0.27) if the test was positive and 0.2*0.09 = 0.02 (probability = 0.02) if the test was negative. A test with a higher positive LR and lower negative LR is considered a better test. Where studies presented more than one estimate of test performance for the same test (e.g., at different cut-off points or for different patient subgroups) we only included one estimate in the pooled analysis. We aimed to select the data set most similar to the estimates provided by the other studies in terms of patient population.

Data on diagnostic performance were also synthesized using the summary receiver operating characteristic (SROC) approach, which is a measure of test accuracy. 21 The ROC curve is a plot of true positive rate (sensitivity) versus the false positive rate (1 - specificity) for various possible cutpoints of a diagnostic test. The closer the curve follows the left hand and top borders of the ROC curve space, the more accurate the test is, while a test of lower accuracy will come closer to the 45 degree diagonal. Thus, the area under the curve is indicative of the accuracy of a diagnostic test, where area of 1.0 represents a perfect test; an area of 0.5 represents a worthless test.

Homogeneity tests were carried out to evaluate the consistency of findings across the studies. We used the I^2^ statistic to determine the percentage of total variation in the LR across the studies due to heterogeneity rather than to chance. 22 A value of 0 percent indicates no observed heterogeneity. I^2^ values of 25, 50 and 75 percent were used as anchors in guiding the classification of meta-analyses into low, moderate and high heterogeneity categories, respectively, 22 where larger values indicate increased heterogeneity. Possible reasons for heterogeneity, such as patient characteristics and the nature of the reference method (biopsy/histology, clinical followup or a composite reference standard) were explored. All analyses were performed using RevMan software version 5.0 (Cochrane Collaboration, Oxford, UK).