# Introduction

## Background

Positron emission tomography (PET) is a form of nuclear medicine imaging that detects and establishes metabolic abnormalities in tissue. A PET scanner produces an image of the area of interest through the detection of radiation emitted from a positron-emitting radionuclide that is introduced into the patient and that accumulates in the target tissue.

Different radiotracers allow for various aspects of tumor metabolism to be imaged. The most commonly used radioisotope tracer is ^18^F-fluorodeoxyglucose (^18^FDG), a glucose analog with the addition of a radioactive fluorine atom, which has a half-life of 109.8 minutes. The relatively long half-life of this radioisotope allows the operation of imaging sites up to 2 to 4 hours travelling distance from the production site. 1 Like glucose, ^18^FDG is taken up into cells through glucose transport proteins (GLUT) and then phosphorylated by a hexokinase. At this point glucose is further metabolized while deoxyglucose is not, leaving the ^18^FDG to accumulate intra-cellularly as ^18^F-FDG-6-phosphate. Images may be interpreted qualitatively by visual assessment for regions of increased uptake. Quantitative measurement of the glucose metabolism by cells in a region of interest is performed using the standardized uptake value (SUV). The SUV is calculated by measuring the tissue radioactivity concentration (µCi/mL) and dividing by the total injected dose (µCi/kg), normalized to the patient’s body weight. Results may be variable depending upon the scanner image resolution, time of image acquisition after radioisotope injection (later images will have higher SUVs as ^18^FDG accumulates), the presence of hyperglycemia, method of normalization (use of body surface area or lean body mass), and the method of quantitative measurement.

Compared to structural imaging techniques (X-ray, computed tomography [CT], and magnetic resonance imaging [MRI]), ^18^FDG-PET may be a more accurate technique for diagnosis, staging, and treatment decisions in oncology. It has been suggested that PET imaging may be able to differentiate between benign and malignant lesions (detecting malignancies as small as 6 millimeters, allowing for the early detection of disease before structural changes become apparent), establish the grade of malignancy (the stage of disease, the existence of recurrent or residual disease, the site of the disease and the primary site of a tumor for biopsy), evaluate a patient’s response to therapy, and can be used for radiotherapy planning in certain types of tumors. 2 Thus, ^18^FDG-PET holds promise for decreasing the utilization of other diagnostic tests and invasive procedures, and providing more accurate knowledge about the extent of the disease. This information may influence patient management decisions, such as the aggressiveness of planned chemotherapy or radiotherapy, which, in turn may significantly impact patient mortality and quality of life. 3

Several authors have discussed the sequence of evaluations that can be done in a diagnostic test study. 4,5 These include diagnostic test performance, therapeutic impact and clinical outcome.

The diagnostic performance of a test can be evaluated based on its sensitivity, specificity, accuracy or likelihood ratios (LR). Evaluating a test’s performance involves comparing test results against a valid reference or “gold” standard, which represents the actual or accepted disease status. Appropriate reference standards can include pathology findings (e.g., histopathological confirmation of the presence or absence of disease) or clinical outcome (e.g., subsequent disease progression or resolution of symptoms and signs).

Therapeutic impact is measured as the change in treatment decision, or decision for additional diagnostic workup, made by clinicians in response to the information provided by the test. The evaluation of outcome assesses if, and to what degree, the patients who had the test have better health outcomes. This can be assessed by randomized controlled trials (RCT) of the test and subsequent management resulting from test information. Changes in outcome may also be reasonably inferred from a combination of evidence of improved diagnostic accuracy, evidence of changes in management and evidence of the effective treatment of a given condition. That is, in conjunction with evidence of improved diagnostic accuracy and changes in management, there should be evidence (ideally from RCTs) that alternative treatment or management results in improved long term health outcomes for patients. For example, if a diagnostic test allowed earlier diagnosis of a condition, evidence that earlier treatment is more effective than delayed treatment is needed to infer that improved outcomes result from the diagnostic test result.

^18^FDG-PET is considered a potentially major advancement in clinical practice because it can provide information about the behavior of tumors in addition to the anatomic extent and thus may provide evidence to guide therapeutic choices. 6 The use of ^18^FDG-PET for the diagnosis of several cancers has been evaluated, 6-9 and it is estimated that applications of ^18^FDG-PET in oncology may soon account for 80 to 90 percent of the technology’s utilization. 2 In the United States, the Centers for Medicaid and Medicare Services (CMS) has determined that there is sufficient evidence to show that a ^18^FDG-PET scan is reasonable and necessary for certain indications in the pretreatment and management phase of non-small cell lung cancer, esophageal cancer, colorectal cancer, lymphoma, melanoma, breast cancer, head and neck cancers and thyroid cancer. 10 Since the decision by the CMS to cover PET for these cancers, the use of PET scanning has increased anywhere from 80 percent for esophageal and brain cancer to 128 percent for head and neck cancers, based on claims data from 2001-2004. Increases of over 1,000 percent were recorded for the initial coverage period 1999-2001 for lymphoma. 11 The issue of assessing ^18^FDG-PET for a range of other cancers currently designated as “coverage with evidence development” remains unaddressed. “Coverage with evidence development” refers to the designation of a ^18^FDG-PET scan being considered “reasonable and necessary” only when the provider is participating in, and patients are enrolled in a prospective clinical study designed to collect additional information to assist in patient management.10

With the exception of central nervous system (CNS) neoplasms, PET for oncologic indications has only been in use since 1995 when the first scanners capable of whole body imaging were introduced. Despite the rapidly expanding evidence for the use of PET, 2 researchers have noted the small number of high-quality ^18^FDG-PET studies and uncertainty surrounding the possibility of publication bias. 3 There remain many unanswered questions with respect to the diagnostic accuracy of ^18^FDG-PET for other cancers and the role of ^18^FDG-PET in grading, restaging and monitoring response to treatment. In addition, because of its putative high cost, 12 ($179.4 million was paid by CMS to providers and facilities for 112,729 PET scans in 2002) 13 it would be beneficial to assess the cost-effectiveness of ^18^FDG-PET in light of the most recent reports of the technology’s clinical effectiveness.

## Scope of the report

In 2004, the Duke Evidence-based Practice Center (EPC) completed a technology assessment on the evidence produced from 1966 to 2003 regarding the utility of PET for six cancers: brain, cervical, small-cell lung, ovarian, pancreatic and testicular. 14 This technology assessment suggested that PET might be beneficial in helping physicians with clinical questions such as staging and detecting metastatic disease and recurrence. However, the literature had many limitations including the use of older generation technology, inclusion of heterogeneous groups of patients without presentation of results by clinically relevant subgroups, absence of data that would allow the reader to infer the information contributed by PET beyond what was available from conventional studies, and in some cases, lack of a comparator.

The National Oncologic PET Registry (NOPR) was launched in May 2006 in response to the CMS “Coverage with evidence development” policy to collect data through a clinical registry to inform the CMS’s ^18^FDG-PET coverage determination decisions for currently non-covered cancer indications. Since then, NOPR has collected questionnaire data from referring physicians on intended patient management before and after an ^18^FDG-PET scan. One publication from the NOPR Working Group15 has reviewed survey data from referring physicians regarding changes in treatment decisions before and after ^18^FDG-PET. The authors found that clinicians report they often change their intended management based on the ^18^FDG-PET results. ^18^FDG-PET was associated with a 36.5 percent change in the treatment or no-treatment decisions. One of the limitations of the NOPR database is that the registry does not document whether the physicians actually completed the planned management changes. Therefore the information is based on an intention-to-treat approach, and the relative impact of ^18^FDG-PET on the actual management of patients with cancer has not been assessed. Recently, NOPR has formally asked CMS to reconsider the current national coverage decision on ^18^FDG-PET and to end the data collection requirements for diagnosis, staging and restaging. CMS will review the published data and determine the next steps related to reimbursement for ^18^FDG-PET scans now only covered through the NOPR.

The Coverage and Analysis Group at CMS requested from The Technology Assessment Program (TAP) at the Agency for Healthcare Research and Quality (AHRQ) that an evaluation be performed on the available scientific evidence on the use of ^18^FDG-PET for nine different cancers (bladder, brain, cervical, kidney, ovarian, pancreatic, prostate, small cell lung, and testicular). AHRQ assigned this evaluation and report to the following Evidence-based Practice Center: the University of Alberta/Capital Health Evidence-based Practice Center (U of A EPC; Contract Number HHSA 290 2007 10021 I).

## Structure of the Report

To provide a framework for the report, we first present the key questions and our analytic approach to address them. Next, a general methods section applicable to all the cancers considered in the report is presented. We describe the literature review methods, outline our inclusion and exclusion criteria, the search strategy for identifying articles relevant to the key questions, and the process for abstracting and synthesizing information from eligible studies. We also describe the methods for assessing the methodological quality of individual studies, the data analysis and synthesis.

The results are reported by type of cancer; each section addressing a particular cancer is organized so that it can be considered a stand-alone report. The bibliography of included studies and appendices, including the search strings, data extraction and quality assessment forms and detailed evidence tables for each cancer, have been placed at the end of the document.

The following four key questions examine the degree to which current evidence supports confident judgments about the use of ^18^FDG-PET in the assessment and treatment of nine types of cancer in clinical practice. It encompasses both dedicated PET and newer PET/CT technology that integrates PET and CT into one device.

### Q1 ^18^FDG-PET and ^18^FDG-PET/CT diagnostic test performance

How does the diagnostic test performance of ^18^FDG-PET and ^18^FDG-PET/CT compare to conventional imaging modalities (e.g., CT and MRI) or other diagnostic procedures (e.g., biopsy, serum tumor markers) with respect to the following clinical situations:

1. Diagnosis
2. Staging
3. Restaging
4. Monitoring response to treatment

### Q2 Diagnostic thinking impact of ^18^FDG-PET and ^18^FDG-PET/CT

What is the magnitude of the impact of ^18^FDG-PET and ^18^FDG-PET/CT on physician decision making regarding approaches to diagnosis and management with respect to the following clinical situations:

1. Diagnosis
2. Staging
3. Restaging
4. Monitoring response to treatment

### Q3 ^18^FDG-PET and ^18^FDG-PET/CT as part of a management strategy

What is the impact of ^18^FDG-PET and ^18^FDG-PET/CT as part of a management strategy to improve patient-centered outcomes? What is the ability of ^18^FDG-PET and ^18^FDG-PET/CT to improve patient-centered outcomes when used as a diagnostic test to identify patients suitable for a particular treatment?

### Q4 Cost-effectiveness of ^18^FDG-PET and ^18^FDG-PET/CT

What is the cost-effectiveness of ^18^FDG-PET and ^18^FDG-PET/CT with respect to the following clinical situations:

1. Diagnosis
2. Staging
3. Restaging
4. Monitoring response to treatment

The six-tiered efficacy model of technology assessment introduced by Fryback and Thornbury16 was used as a framework to quantify the level of evidence available to address the questions of this report (Table 1). This report focuses on all evidence between levels 2 and 6 (excluding technical imaging quality data).

Table 1 Hierarchy of Diagnostic Efficacy

Level of evidence | Description
Level 1: Technical | Resolution of line pairs Modulation transfer function change Gray-scale range Amounts of mottle Sharpness Computerized imaging parameters
Level 2: Diagnostic accuracy efficacy | Yield of abnormal or normal diagnoses in a case series Diagnostic accuracy (percentage of correct diagnoses in case series) Sensitivity, specificity, and positive/negative predictive value in a defined clinical problem setting Measures of area under the receiver operating characteristic (ROC) curve
Level 3: Diagnostic thinking efficacy | Number (percentage) of cases in a series in which image was judged “helpful” for making the diagnosis Entropy change in differential diagnosis probability distribution Difference in clinicians’ subjectively estimated diagnosis probabilities before and after test information
Level 4: Therapeutic efficacy | Number (percentage) of times image was judged “helpful” in planning patient care in a case series Percentage of times medical or surgical procedure avoided due to image information Number or percentage of times planned therapy pretest changed after the image information was obtained (retrospectively inferred from clinical records) Number or percentage of times clinicians’ prospectively stated therapeutic choices changed after test information
Level 5: Patient outcome efficacy | Percentage of patients improved with test v. without test Morbidity (or procedures) avoided after having image information Change in quality-adjusted life expectancy Expected value of test information in quality-adjusted life years (QALYs) Cost per QALY saved with image information Patient utility assessment (e.g., Markov modeling, time trade-off)
Level 6: Societal efficacy | Benefit-cost analysis from societal viewpoint Cost-effectiveness analysis from societal viewpoint