# Methodological Characteristics of Studies Relevant to Question 4

| | | | Quality Components
| Study population clearly described | Appropriate economic study design | Perspective appropriate | Costs measured appropriately in physical units | Outcomes valued appropriately | Future costs and outcomes discounted | Discussion of generalizability of results
| Competing alternatives clearly described | Time horizon appropriate | Relevant costs for each alternative identified | Costs valued appropriately | Incremental cost analysis performed | Sensitivity analysis | Ethical and distributional issues discussed
Heinrich S, 2005^95^ Cancer type: Pancreatic Questions: Q4 | Yes | Yes | Partial | Partial | Yes | Yes | Yes
Heinrich S, 2005^95^ Cancer type: Pancreatic Questions: Q4 | Partial | Yes | Partial | Partial | Yes | Partial | Partial