# Methodological Characteristics of Studies Relevant to Question 3

| Quality Components
| Objective/hypothesis of study | Use of prospective design | Allocation concealment | PET-FDG group and control group comparable | Co-interventions were the same in each group | Defined criteria for FDG-PET interpretation | FDG-PET interpretation blinded to other results
| Selection criteria clearly described | Randomization to study groups | Control group for comparison | PET-FDG described in sufficient detail to permit replication | Time for outcome assessment/follow-up similar in all groups | More than one person interpreted test results | Outcome assessment blind to treatment group
Padma MV, 2003^129^ Cancer type: Brain Questions: Q3 | Well defined | No | Unclear | No | Yes | Yes | Yes
Padma MV, 2003^129^ Cancer type: Brain Questions: Q3 | Partial | No | No | Inadequate | Yes | Yes | Yes
Chang TC, 2004^33^ Cancer type: Cervical Questions: Q3 | Well defined | Yes | Unclear | Unclear | Yes | Yes | Unclear
Chang TC, 2004^33^ Cancer type: Cervical Questions: Q3 | Adequate | No | Yes | Partial | Unclear | Yes | Yes
Lai CH, 2004^42^ Cancer type: Cervical Questions: Q3 | Well defined | Yes | NA | Unclear | Yes | Yes | Unclear
Lai CH, 2004^42^ Cancer type: Cervical Questions: Q3 | Adequate | No | Yes | Adequate | Yes | Yes | Unclear
Kim S, 2004^130^ Cancer type: Ovarian Questions: Q3 | Well defined | No | Unclear | Yes | Yes | Yes | Unclear
Kim S, 2004^130^ Cancer type: Ovarian Questions: Q3 | Inadequate | No | Yes | Adequate | Yes | Yes | Unclear
Bang S, 2006^91^ Cancer type: Pancreatic Questions: Q3 | Well defined | Yes | NA | Unclear | Yes | Yes | Yes
Bang S, 2006^91^ Cancer type: Pancreatic Questions: Q3 | Inadequate | No | Yes | Adequate | Yes | Yes | No