# Methodological Characteristics of Studies Relevant to Questions 1 and 2

| Quality Components
| Representativeness of patient spectrum | Reference standard likely to classify the condition correctly | Whole sample, or a random selection of the sample received verification | Reference standard independent of the index test | Reference standard described in sufficient detail to permit replication | Reference results interpreted without knowledge of index test results | Explanation for withdrawals from the study
| Selection criteria clearly described | Period between reference standard and index test is reasonable | Same reference standard regardless of the index test result | Index test described in sufficient detail to permit replication | Index test results interpreted without knowledge of reference standard results | Uninterpretable or intermediate test results reported | Clinical data available when test results were interpreted as would be available when the test is used in practice
Drieskens O, 2005^23^ Cancer type: Bladder Questions: Q1 | Partially | Yes | No | Yes | Partially | Unclear | Yes
Drieskens O, 2005^23^ Cancer type: Bladder Questions: Q1 | Yes | Yes | Partially | Partially | Yes | Yes | Yes
Jadvar H, 2008^24^ Cancer type: Bladder Questions: Q1, Q2 | Yes | Yes | Yes | Yes | Partially | Unclear | Yes
Jadvar H, 2008^24^ Cancer type: Bladder Questions: Q1, Q2 | Partially | Unclear | Partially | Yes | No | Yes | Yes
Liu IJ, 2003^25^ Cancer type: Bladder Questions: Q1 | Partially | Yes | Yes | Yes | Partially | Unclear | Yes
Liu IJ, 2003^25^ Cancer type: Bladder Questions: Q1 | Partially | Unclear | Partially | Partially | Yes | Yes | Unclear
Chen W, 2006^26^ Cancer type: Brain Questions: Q1 | Partially | Yes | Yes | Yes | No | Unclear | Yes
Chen W, 2006^26^ Cancer type: Brain Questions: Q1 | No | Yes | Partially | Partially | Yes | Yes | Yes
Cher LM, 2006^27^ Cancer type: Brain Questions: Q1 | Partially | Yes | Yes | Yes | Partially | Unclear | Yes
Cher LM, 2006^27^ Cancer type: Brain Questions: Q1 | Partially | Yes | Partially | No | Yes | Yes | Yes
Liu RS, 2006^28^ Cancer type: Brain Questions: Q1 | Yes | Yes | Yes | Yes | No | Unclear | Yes
Liu RS, 2006^28^ Cancer type: Brain Questions: Q1 | Partially | Unclear | Yes | Yes | Unclear | Yes | Yes
Potzi C, 2007^29^ Cancer type: Brain Questions: Q1 | Yes | Yes | Yes | Yes | No | Unclear | Yes
Potzi C, 2007^29^ Cancer type: Brain Questions: Q1 | Yes | Yes | Partially | Yes | No | Yes | No
Stockhammer F, 2007^30^ Cancer type: Brain Questions: Q1 | Unclear | Yes | Yes | Yes | Yes | Unclear | Yes
Stockhammer F, 2007^30^ Cancer type: Brain Questions: Q1 | Yes | Unclear | Yes | Partially | Yes | Yes | Unclear
Amit A, 2006^31^ Cancer type: Cervical Questions: Q1 | Unclear | Yes | Yes | Yes | Partially | No | Yes
Amit A, 2006^31^ Cancer type: Cervical Questions: Q1 | Partially | Unclear | Partially | Partially | Yes | Yes | Yes
Bjurberg M, 2007^32^ Cancer type: Cervical Questions: Q1, Q2 | Yes | Yes | Yes | Yes | Partially | Unclear | Yes
Bjurberg M, 2007^32^ Cancer type: Cervical Questions: Q1, Q2 | Yes | Unclear | Partially | Partially | Unclear | Yes | Yes
Chang TC, 2004^33^ Cancer type: Cervical Questions: Q1, Q2 | Partially | Yes | Yes | Yes | Yes | No | Yes
Chang TC, 2004^33^ Cancer type: Cervical Questions: Q1, Q2 | Yes | Yes | Partially | Yes | Unclear | Yes | Yes
Chang WC, 2004^34^ Cancer type: Cervical Questions: Q1 | Yes | Yes | Yes | Yes | No | No | Yes
Chang WC, 2004^34^ Cancer type: Cervical Questions: Q1 | Yes | Partially | Partially | Yes | Yes | Yes | Yes
Chang YC, 2005^35^ Cancer type: Cervical Questions: Q1 | Yes | Yes | Yes | Yes | Partially | Unclear | Yes
Chang YC, 2005^35^ Cancer type: Cervical Questions: Q1 | Yes | Yes | Partially | Yes | Yes | Yes | No
Choi HJ, 2006^36^ Cancer type: Cervical Questions: Q1 | Unclear | Yes | Yes | Yes | Yes | No | Yes
Choi HJ, 2006^36^ Cancer type: Cervical Questions: Q1 | Yes | Yes | Yes | Yes | Yes | Yes | Unclear
Chou HH, 2006^37^ Cancer type: Cervical Questions: Q1 | Partially | Yes | Yes | Yes | Yes | Unclear | Yes
Chou HH, 2006^37^ Cancer type: Cervical Questions: Q1 | Yes | Yes | Yes | Partially | Yes | Yes | Unclear
Chung HH, 2006^39^ Cancer type: Cervical Questions: Q1 | Yes | Yes | Yes | Yes | Partially | No | Yes
Chung HH, 2006^39^ Cancer type: Cervical Questions: Q1 | Yes | Unclear | Partially | Partially | Yes | Yes | Unclear
Chung HH, 2007^38^ Cancer type: Cervical Questions: Q1, Q2 | Partially | Yes | Yes | Yes | Partially | Unclear | Yes
Chung HH, 2007^38^ Cancer type: Cervical Questions: Q1, Q2 | Yes | Unclear | Partially | No | Yes | Yes | Yes
Havrilesky LJ, 2003^40^ Cancer type: Cervical Questions: Q1 | Yes | Yes | Yes | Yes | No | Unclear | Yes
Havrilesky LJ, 2003^40^ Cancer type: Cervical Questions: Q1 | Yes | Yes | Partially | Yes | Yes | Yes | Yes
Hope AJ, 2006^41^ Cancer type: Cervical Questions: Q1 | Unclear | Yes | Yes | Yes | No | Yes | Yes
Hope AJ, 2006^41^ Cancer type: Cervical Questions: Q1 | Yes | Unclear | Yes | No | Unclear | Yes | Unclear
Lai CH, 2004^42^ Cancer type: Cervical Questions: Q1, Q2 | Partially | Yes | Yes | Yes | Yes | Unclear | Yes
Lai CH, 2004^42^ Cancer type: Cervical Questions: Q1, Q2 | Yes | Yes | Partially | Yes | Unclear | Yes | Unclear
Lin CT, 2006^43^ Cancer type: Cervical Questions: Q1, Q2 | Partially | Yes | Yes | Yes | Yes | Unclear | Yes
Lin CT, 2006^43^ Cancer type: Cervical Questions: Q1, Q2 | Yes | Yes | Partially | Partially | Yes | Yes | No
Lin WC, 2003^44^ Cancer type: Cervical Questions: Q1 | No | Yes | Yes | Yes | No | Unclear | Yes
Lin WC, 2003^44^ Cancer type: Cervical Questions: Q1 | Yes | Unclear | Yes | Yes | No | Yes | Unclear
Loft A, 2007^45^ Cancer type: Cervical Questions: Q1 | Partially | Yes | Yes | Yes | Partially | No | Yes
Loft A, 2007^45^ Cancer type: Cervical Questions: Q1 | Yes | Yes | Partially | Yes | Yes | Yes | Unclear
Ma SY, 2003^46^ Cancer type: Cervical Questions: Q1 | Yes | Yes | Yes | Yes | Partially | Unclear | Yes
Ma SY, 2003^46^ Cancer type: Cervical Questions: Q1 | Yes | Yes | Partially | Partially | Yes | Yes | No
Park W, 2005^47^ Cancer type: Cervical Questions: Q1 | Partially | Yes | Yes | Yes | Partially | No | Yes
Park W, 2005^47^ Cancer type: Cervical Questions: Q1 | No | Yes | Yes | Partially | Yes | Yes | No
Roh JW, 2005^48^ Cancer type: Cervical Questions: Q1 | Partially | Yes | Yes | Yes | Partially | Unclear | Yes
Roh JW, 2005^48^ Cancer type: Cervical Questions: Q1 | Yes | Unclear | Yes | Yes | Yes | Yes | Unclear
Ryu SY, 2003^49^ Cancer type: Cervical Questions: Q1 | Yes | Yes | Partially | Yes | No | Unclear | Yes
Ryu SY, 2003^49^ Cancer type: Cervical Questions: Q1 | Yes | Unclear | Partially | Yes | Yes | Yes | No
Sakurai H, 2006^50^ Cancer type: Cervical Questions: Q1 | Partially | Partially | Yes | Yes | No | Unclear | Yes
Sakurai H, 2006^50^ Cancer type: Cervical Questions: Q1 | No | Partially | Partially | Partially | Unclear | Unclear | Unclear
Sironi S, 2006^51^ Cancer type: Cervical Questions: Q1 | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Sironi S, 2006^51^ Cancer type: Cervical Questions: Q1 | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Sironi S, 2007^52^ Cancer type: Cervical Questions: Q1 | Yes | Yes | Yes | Yes | Yes | No | Yes
Sironi S, 2007^52^ Cancer type: Cervical Questions: Q1 | Yes | Yes | Partially | Yes | Yes | Yes | Unclear
Tran BN, 2003^53^ Cancer type: Cervical Questions: Q1 | Partially | Yes | Yes | Yes | No | Unclear | Yes
Tran BN, 2003^53^ Cancer type: Cervical Questions: Q1 | Yes | Unclear | Yes | Partially | Yes | Yes | Yes
Unger JB, 2004^54^ Cancer type: Cervical Questions: Q1 | Partially | Yes | Yes | Yes | No | No | No
Unger JB, 2004^54^ Cancer type: Cervical Questions: Q1 | Yes | Yes | Partially | Partially | Yes | Yes | Unclear
Unger JB, 2005^55^ Cancer type: Cervical Questions: Q1 | Partially | Yes | Yes | Yes | No | No | Yes
Unger JB, 2005^55^ Cancer type: Cervical Questions: Q1 | Yes | Unclear | Yes | Partially | Yes | Yes | Unclear
Van Der Veldt AAM, 2006^56^ Cancer type: Cervical Questions: Q1 | Yes | Yes | Yes | Yes | Partially | Unclear | Yes
Van Der Veldt AAM, 2006^56^ Cancer type: Cervical Questions: Q1 | Yes | Partially | Partially | Partially | Yes | Yes | No
Wong TZ, 2004^57^ Cancer type: Cervical Questions: Q1 | Partially | Yes | Yes | Yes | No | No | Yes
Wong TZ, 2004^57^ Cancer type: Cervical Questions: Q1 | Yes | Yes | Partially | Yes | No | Yes | Yes
Wright JD, 2005^58^ Cancer type: Cervical Questions: Q1 | Partially | Yes | Yes | Yes | No | No | Yes
Wright JD, 2005^58^ Cancer type: Cervical Questions: Q1 | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Yen TC, 2003^60^ Cancer type: Cervical Questions: Q1 | Yes | Yes | Yes | No | No | Unclear | Yes
Yen TC, 2003^60^ Cancer type: Cervical Questions: Q1 | Yes | Yes | Partially | Yes | Yes | Yes | Unclear
Yen TC, 2004^61^ Cancer type: Cervical Questions: Q1, Q2 | Unclear | Yes | Yes | Yes | Partially | Unclear | Yes
Yen TC, 2004^61^ Cancer type: Cervical Questions: Q1, Q2 | Yes | Yes | Partially | Partially | Unclear | Yes | Unclear
Yen TC, 2006^59^ Cancer type: Cervical Questions: Q1 | Partially | Yes | Yes | Yes | Partially | Unclear | Yes
Yen TC, 2006^59^ Cancer type: Cervical Questions: Q1 | Yes | Partially | Partially | Partially | Yes | Yes | Unclear
Yildirim Y, 2008^62^ Cancer type: Cervical Questions: Q1 | Partially | Yes | Yes | Yes | Yes | Yes | Yes
Yildirim Y, 2008^62^ Cancer type: Cervical Questions: Q1 | Yes | Yes | Yes | Partially | Yes | Yes | No
Grisaru D, 2004^63^ Cancer type: Cervical and Ovarian Questions: Q1 | Yes | Yes | Yes | Yes | No | Unclear | Yes
Grisaru D, 2004^63^ Cancer type: Cervical and Ovarian Questions: Q1 | Yes | Unclear | Partially | Partially | Yes | Yes | Unclear
Aide N, 2003^64^ Cancer type: Kidney Questions: Q1 | Yes | Yes | Yes | Yes | Partially | No | Yes
Aide N, 2003^64^ Cancer type: Kidney Questions: Q1 | Partially | Yes | Partially | Yes | Yes | Yes | Unclear
Ak I, 2005^65^ Cancer type: Kidney Questions: Q1 | Partially | Yes | Yes | Yes | No | Unclear | Yes
Ak I, 2005^65^ Cancer type: Kidney Questions: Q1 | No | Yes | Yes | Partially | Yes | Yes | Yes
Chang CH, 2003^66^ Cancer type: Kidney Questions: Q1 | Partially | Yes | Yes | Yes | No | No | Yes
Chang CH, 2003^66^ Cancer type: Kidney Questions: Q1 | Yes | Unclear | Yes | Yes | Yes | Yes | Unclear
Dilhuydy MS, 2006^67^ Cancer type: Kidney Questions: Q1, Q2 | Partially | Yes | Yes | Yes | Partially | Unclear | Yes
Dilhuydy MS, 2006^67^ Cancer type: Kidney Questions: Q1, Q2 | Partially | Yes | Partially | Partially | No | Yes | Yes
Jadvar H, 2003^68^ Cancer type: Kidney Questions: Q1 | Partially | Yes | Yes | Yes | No | No | Yes
Jadvar H, 2003^68^ Cancer type: Kidney Questions: Q1 | Partially | Yes | Partially | Partially | Yes | Yes | Yes
Kang DE, 2004^69^ Cancer type: Kidney Questions: Q1, Q2 | Yes | Yes | Yes | Yes | Partially | Unclear | Unclear
Kang DE, 2004^69^ Cancer type: Kidney Questions: Q1, Q2 | Yes | Yes | Partially | No | No | Yes | Yes
Kumar R, 2005^70^ Cancer type: Kidney Questions: Q1, Q2 | Partially | Yes | Yes | No | No | Unclear | Yes
Kumar R, 2005^70^ Cancer type: Kidney Questions: Q1, Q2 | Partially | Yes | Partially | Partially | Unclear | Yes | Yes
Majhail NS, 2003^71^ Cancer type: Kidney Questions: Q1 | Yes | Yes | Yes | Yes | No | Unclear | Yes
Majhail NS, 2003^71^ Cancer type: Kidney Questions: Q1 | Partially | Yes | Yes | Yes | Yes | Yes | Yes
Bristow RE, 2003^72^ Cancer type: Ovarian Questions: Q1 | Partially | Yes | Yes | Yes | Partially | Unclear | Yes
Bristow RE, 2003^72^ Cancer type: Ovarian Questions: Q1 | Yes | Yes | Yes | Yes | Yes | Yes | Unclear
Bristow RE, 2005^73^ Cancer type: Ovarian Questions: Q1 | Yes | Yes | Yes | Yes | Partially | No | Yes
Bristow RE, 2005^73^ Cancer type: Ovarian Questions: Q1 | Yes | Yes | Yes | Yes | Yes | Yes | Unclear
Castellucci P, 2007^74^ Cancer type: Ovarian Questions: Q1 | Yes | Yes | Yes | Yes | Yes | Unclear | Yes
Castellucci P, 2007^74^ Cancer type: Ovarian Questions: Q1 | Yes | Yes | Yes | Partially | Yes | Yes | Yes
Chung HH, 2007^75^ Cancer type: Ovarian Questions: Q1,Q2 | Yes | Yes | Yes | Yes | Partially | Unclear | Yes
Chung HH, 2007^75^ Cancer type: Ovarian Questions: Q1,Q2 | Yes | Unclear | Partially | Yes | Yes | Yes | Unclear
Drieskens O, 2003^76^ Cancer type: Ovarian Questions: Q1 | Partially | Yes | Yes | Yes | No | Unclear | Yes
Drieskens O, 2003^76^ Cancer type: Ovarian Questions: Q1 | Partially | Yes | Partially | Partially | Yes | Yes | No
Garcia-Velloso MJ, 2007^77^ Cancer type: Ovarian Questions: Q1 | Partially | Yes | Yes | Yes | Partially | No | Yes
Garcia-Velloso MJ, 2007^77^ Cancer type: Ovarian Questions: Q1 | Partially | Unclear | Partially | Partially | Yes | Yes | Unclear
Hauth EA, 2005^78^ Cancer type: Ovarian Questions: Q1 | Unclear | Yes | Yes | No | Partially | Unclear | Yes
Hauth EA, 2005^78^ Cancer type: Ovarian Questions: Q1 | Partially | Yes | Partially | Yes | Yes | Yes | Unclear
Kawahara K, 2004^79^ Cancer type: Ovarian Questions: Q1 | Yes | Yes | Yes | Yes | Partially | Unclear | Yes
Kawahara K, 2004^79^ Cancer type: Ovarian Questions: Q1 | Yes | Yes | Yes | Yes | Yes | Yes | Unclear
Kim CK, 2007^80^ Cancer type: Ovarian Questions: Q1 | Yes | Yes | Yes | Yes | Yes | No | Yes
Kim CK, 2007^80^ Cancer type: Ovarian Questions: Q1 | Partially | Yes | Partially | Yes | Yes | Yes | No
Mangili G, 2007^126^ Cancer type: Ovarian Questions: Q2 | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Mangili G, 2007^126^ Cancer type: Ovarian Questions: Q2 | Partially | Unclear | Partially | Partially | No | Yes | Yes
Murakami M, 2006^81^ Cancer type: Ovarian Questions: Q1 | Partially | Yes | Yes | Yes | Partially | Unclear | Yes
Murakami M, 2006^81^ Cancer type: Ovarian Questions: Q1 | Yes | Yes | Partially | Yes | Yes | Yes | Unclear
Nanni C, 2005^82^ Cancer type: Ovarian Questions: Q1 | Yes | Yes | Yes | No | Partially | Unclear | Yes
Nanni C, 2005^82^ Cancer type: Ovarian Questions: Q1 | Partially | Yes | Partially | Partially | Yes | Yes | No
Pannu HK, 2004^83^ Cancer type: Ovarian Questions: Q1 | Partially | Yes | Yes | Yes | No | No | Yes
Pannu HK, 2004^83^ Cancer type: Ovarian Questions: Q1 | Yes | Yes | Yes | Yes | Yes | Yes | Unclear
Picchio M, 2003^84^ Cancer type: Ovarian Questions: Q1 | Unclear | Yes | Yes | Yes | Yes | No | Yes
Picchio M, 2003^84^ Cancer type: Ovarian Questions: Q1 | Partially | Yes | Yes | Yes | Yes | Yes | Yes
Risum S, 2007^85^ Cancer type: Ovarian Questions: Q1 | Yes | Yes | Yes | Yes | Yes | Unclear | Yes
Risum S, 2007^85^ Cancer type: Ovarian Questions: Q1 | Yes | Yes | Yes | Yes | Yes | Yes | Unclear
Sebastian S, 2008^86^ Cancer type: Ovarian Questions: Q1 | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Sebastian S, 2008^86^ Cancer type: Ovarian Questions: Q1 | Yes | Yes | Partially | Partially | Yes | Yes | Unclear
Simcock B, 2006^127^ Cancer type: Ovarian Questions: Q2 | Partially | Yes | Yes | Yes | No | No | Yes
Simcock B, 2006^127^ Cancer type: Ovarian Questions: Q2 | Yes | Partially | Partially | Partially | No | Yes | Unclear
Sironi S, 2004^87^ Cancer type: Ovarian Questions: Q1 | Yes | Yes | Yes | Yes | Yes | No | Yes
Sironi S, 2004^87^ Cancer type: Ovarian Questions: Q1 | Yes | Yes | Yes | Yes | Yes | Yes | No
Soussan M, 2008^128^ Cancer type: Ovarian Questions: Q2 | Partially | Yes | Yes | Yes | Yes | Unclear | Yes
Soussan M, 2008^128^ Cancer type: Ovarian Questions: Q2 | Partially | Yes | Yes | Yes | Unclear | Yes | No
Takekuma M, 2005^88^ Cancer type: Ovarian Questions: Q1 | Partially | Yes | Yes | Yes | No | Unclear | Yes
Takekuma M, 2005^88^ Cancer type: Ovarian Questions: Q1 | Yes | Yes | Partially | No | Yes | Yes | Unclear
Thrall MM, 2007^89^ Cancer type: Ovarian Questions: Q1, Q2 | Yes | Yes | Yes | Yes | Yes | No | Yes
Thrall MM, 2007^89^ Cancer type: Ovarian Questions: Q1, Q2 | Yes | Partially | Partially | Yes | Yes | Yes | Unclear
Yoshida Y, 2004^90^ Cancer type: Ovarian Questions: Q1 | Yes | Yes | Yes | Yes | Yes | Unclear | Yes
Yoshida Y, 2004^90^ Cancer type: Ovarian Questions: Q1 | Yes | Yes | Yes | Yes | Yes | Yes | No
Bang S, 2006^91^ Cancer type: Pancreatic Questions: Q1, Q2 | Partially | Yes | Yes | Yes | No | Unclear | Yes
Bang S, 2006^91^ Cancer type: Pancreatic Questions: Q1, Q2 | Yes | Partially | Partially | Partially | Yes | Yes | No
Borbath I, 2005^92^ Cancer type: Pancreatic Questions: Q1 | Yes | Yes | Yes | Yes | Yes | No | Yes
Borbath I, 2005^92^ Cancer type: Pancreatic Questions: Q1 | Partially | Partially | Partially | Partially | Yes | Yes | Yes
Casneuf V, 2007^93^ Cancer type: Pancreatic Questions: Q1 | Yes | Yes | Yes | Yes | No | Unclear | Yes
Casneuf V, 2007^93^ Cancer type: Pancreatic Questions: Q1 | Partially | Unclear | Partially | Yes | Yes | Yes | Unclear
Giorgi MC, 2004^94^ Cancer type: Pancreatic Questions: Q1 | Partially | Yes | Yes | Yes | No | Unclear | Yes
Giorgi MC, 2004^94^ Cancer type: Pancreatic Questions: Q1 | Partially | Unclear | Partially | Partially | Yes | Yes | Unclear
Heinrich S, 2005^95^ Cancer type: Pancreatic Questions: Q1, Q2 | Partially | Yes | Yes | Yes | Partially | No | Yes
Heinrich S, 2005^95^ Cancer type: Pancreatic Questions: Q1, Q2 | Partially | Yes | Yes | Yes | Unclear | Yes | Unclear
Lemke AJ, 2004^96^ Cancer type: Pancreatic Questions: Q1 | Partially | Yes | Yes | Yes | No | Unclear | Yes
Lemke AJ, 2004^96^ Cancer type: Pancreatic Questions: Q1 | Yes | Yes | Partially | Partially | Unclear | Yes | Unclear
Lytras D, 2005^97^ Cancer type: Pancreatic Questions: Q1 | Partially | Yes | Yes | Yes | Partially | No | Yes
Lytras D, 2005^97^ Cancer type: Pancreatic Questions: Q1 | Partially | Unclear | Partially | Partially | Yes | Yes | Unclear
Maemura K, 2006^98^ Cancer type: Pancreatic Questions: Q1 | Partially | Yes | Yes | Yes | Partially | Unclear | Yes
Maemura K, 2006^98^ Cancer type: Pancreatic Questions: Q1 | Partially | Unclear | Partially | Yes | Yes | Unclear | Unclear
Mansour JC, 2006^99^ Cancer type: Pancreatic Questions: Q1 | Partially | Yes | Partially | Yes | No | No | Yes
Mansour JC, 2006^99^ Cancer type: Pancreatic Questions: Q1 | Yes | Partially | Partially | No | Yes | Yes | No
Nishiyama Y, 2005^101^ Cancer type: Pancreatic Questions: Q1, Q2 | Yes | Yes | Yes | Yes | Yes | Unclear | Yes
Nishiyama Y, 2005^101^ Cancer type: Pancreatic Questions: Q1, Q2 | Partially | Yes | Partially | Yes | Yes | Yes | Unclear
Nishiyama Y, 2005^100^ Cancer type: Pancreatic Questions: Q1 | Partially | Yes | Yes | No | No | No | Yes
Nishiyama Y, 2005^100^ Cancer type: Pancreatic Questions: Q1 | Yes | Yes | Partially | Yes | Yes | Yes | No
Rasmussen I, 2004^102^ Cancer type: Pancreatic Questions: Q1 | Yes | Yes | Yes | Yes | Partially | Unclear | Yes
Rasmussen I, 2004^102^ Cancer type: Pancreatic Questions: Q1 | Yes | Unclear | Yes | Yes | Yes | Yes | Unclear
Ruf J, 2005^104^ Cancer type: Pancreatic Questions: Q1 | Partially | Yes | Yes | Yes | No | Unclear | Yes
Ruf J, 2005^104^ Cancer type: Pancreatic Questions: Q1 | Yes | Unclear | Partially | Yes | Yes | Yes | No
Ruf J, 2006^103^ Cancer type: Pancreatic Questions: Q1, Q2 | Partially | Yes | Yes | Yes | Yes | No | Yes
Ruf J, 2006^103^ Cancer type: Pancreatic Questions: Q1, Q2 | Yes | Yes | Partially | Yes | No | Yes | Unclear
Sperti C, 2007^105^ Cancer type: Pancreatic Questions: Q1, Q2 | Yes | Yes | Yes | Yes | Yes | Yes | Yes
Sperti C, 2007^105^ Cancer type: Pancreatic Questions: Q1, Q2 | Partially | Unclear | Partially | Yes | Yes | Yes | Unclear
van Kouwen MC, 2005^106^ Cancer type: Pancreatic Questions: Q1 | Partially | Yes | Yes | Yes | No | Unclear | Yes
van Kouwen MC, 2005^106^ Cancer type: Pancreatic Questions: Q1 | Yes | Unclear | Partially | Partially | Yes | Yes | No
Wakabayashi H, 2008^107^ Cancer type: Pancreatic Questions: Q1 | Partially | Yes | Yes | Yes | Partially | Unclear | Yes
Wakabayashi H, 2008^107^ Cancer type: Pancreatic Questions: Q1 | Partially | Unclear | Partially | No | Yes | Yes | Unclear
Chang CH, 2003^108^ Cancer type: Prostate Questions: Q1 | Partially | Yes | Yes | Yes | Yes | Unclear | Yes
Chang CH, 2003^108^ Cancer type: Prostate Questions: Q1 | Partially | Unclear | Yes | Yes | Yes | Yes | No
Jadvar H, 2003^109^ Cancer type: Prostate Questions: Q1 | Partially | Partially | Yes | Yes | No | Unclear | Yes
Jadvar H, 2003^109^ Cancer type: Prostate Questions: Q1 | Partially | Partially | Partially | Partially | No | Yes | Yes
Oyama N, 2003^110^ Cancer type: Prostate Questions: Q1 | Partially | Yes | No | Yes | No | Unclear | Yes
Oyama N, 2003^110^ Cancer type: Prostate Questions: Q1 | Yes | Unclear | Partially | Partially | Yes | Yes | No
Schoder H, 2005^111^ Cancer type: Prostate Questions: Q1 | Yes | Yes | Yes | Yes | Partially | Unclear | Yes
Schoder H, 2005^111^ Cancer type: Prostate Questions: Q1 | Yes | Yes | Partially | Partially | Unclear | Yes | Yes
Blum R, 2004^112^ Cancer type: SCLC Questions: Q1, Q2 | Yes | Yes | Yes | Yes | Partially | Unclear | Yes
Blum R, 2004^112^ Cancer type: SCLC Questions: Q1, Q2 | Partially | Unclear | Partially | Partially | No | Yes | Yes
Bradley JD, 2004^113^ Cancer type: SCLC Questions: Q1, Q2 | Partially | Yes | Yes | Yes | Partially | No | Yes
Bradley JD, 2004^113^ Cancer type: SCLC Questions: Q1, Q2 | Yes | Yes | Yes | Partially | Yes | Yes | Yes
Brink I, 2004^114^ Cancer type: SCLC Questions: Q1 | Yes | Yes | Partially | Yes | Partially | Yes | Yes
Brink I, 2004^114^ Cancer type: SCLC Questions: Q1 | Partially | Unclear | Partially | Yes | Yes | Yes | Unclear
Fischer BM, 2006^115^ Cancer type: SCLC Questions: Q1 | Partially | Partially | Yes | No | No | Unclear | Yes
Fischer BM, 2006^115^ Cancer type: SCLC Questions: Q1 | Yes | Yes | Yes | Partially | Unclear | Yes | Unclear
Fischer BM, 2007^116^ Cancer type: SCLC Questions: Q1 | Partially | Yes | Yes | Yes | Yes | Unclear | Yes
Fischer BM, 2007^116^ Cancer type: SCLC Questions: Q1 | Yes | Yes | Partially | Partially | Yes | Yes | Unclear
Kamel EM, 2003^117^ Cancer type: SCLC Questions: Q1, Q2 | Yes | Yes | Yes | Yes | Partially | No | Yes
Kamel EM, 2003^117^ Cancer type: SCLC Questions: Q1, Q2 | Partially | Unclear | Yes | Yes | No | Yes | Yes
Kut V, 2007^118^ Cancer type: SCLC Questions: Q1 | Partially | Yes | Yes | Yes | No | Unclear | Yes
Kut V, 2007^118^ Cancer type: SCLC Questions: Q1 | Yes | Yes | Partially | Partially | Unclear | Yes | Unclear
Niho S, 2007^119^ Cancer type: SCLC Questions: Q1 | Yes | Yes | Yes | No | Partially | Yes | Yes
Niho S, 2007^119^ Cancer type: SCLC Questions: Q1 | No | Yes | Partially | Yes | No | Yes | Unclear
Pandit N, 2003^120^ Cancer type: SCLC Questions: Q1 | Yes | Yes | Yes | Yes | Partially | No | Yes
Pandit N, 2003^120^ Cancer type: SCLC Questions: Q1 | Partially | Unclear | Partially | Yes | Yes | Yes | No
Vinjamuri M, 2008^121^ Cancer type: SCLC Questions: Q1 | Yes | Yes | Yes | Yes | No | No | Yes
Vinjamuri M, 2008^121^ Cancer type: SCLC Questions: Q1 | Yes | Partially | Partially | No | Yes | Yes | Yes
Becherer A, 2005^122^ Cancer type: Testicular Questions: Q1 | Partially | Yes | Yes | Yes | No | No | Yes
Becherer A, 2005^122^ Cancer type: Testicular Questions: Q1 | Yes | No | Partially | Yes | Yes | Yes | Unclear
Hinz S, 2008^123^ Cancer type: Testicular Questions: Q1 | Partially | Yes | Yes | Yes | Partially | Unclear | Yes
Hinz S, 2008^123^ Cancer type: Testicular Questions: Q1 | Yes | Yes | Yes | Partially | Yes | Yes | Unclear
Karapetis CS, 2003^124^ Cancer type: Testicular Questions: Q1, Q2 | Yes | Unclear | Yes | Yes | No | No | Yes
Karapetis CS, 2003^124^ Cancer type: Testicular Questions: Q1, Q2 | Partially | Unclear | Partially | Partially | Yes | Yes | Yes
Lassen U, 2003^125^ Cancer type: Testicular Questions: Q1 | Yes | Yes | Yes | Yes | No | No | Yes
Lassen U, 2003^125^ Cancer type: Testicular Questions: Q1 | Yes | Partially | Partially | Yes | Yes | Yes | Unclear