# Characteristics of Included Studies in Q4 on the cost-effectiveness of ^18^FDG-PET and ^18^FDG-PET/CT

Pancreatic Cancer