# Characteristics of Included Studies in Q3 on ^18^FDG-PET and ^18^FDG-PET/CT as part of a management strategy

Brain Cancer

Cervical Cancer

Ovarian Cancer

Pancreatic Cancer