# Characteristics of Included Studies in Q2 on the diagnostic thinking impact of ^18^FDG-PET and ^18^FDG-PET/CT

Bladder Cancer

Cervical Cancer

Kidney Cancer

Ovarian Cancer

Pancreatic Cancer

Small Cell Lung Cancer

Testicular Cancer