# Characteristics of Included Studies for Q1 on the diagnostic test performance of ^18^FDG-PET and ^18^FDG-PET/CT

Bladder Cancer

Brain Cancer

Cervical Cancer

Kidney Cancer

Ovarian Cancer

Pancreatic Cancer

Prostate Cancer

Small Cell Lung Cancer

Testicular Cancer