# Excluded Studies

Two hundred and ninety studies were excluded. The reasons for exclusion are as follows: (1) the study did not provide data to evaluate any of the research questions considered in the TA (n= 93), (2) the study did not use a matched design (n= 28), (3) the study did not evaluate ^18^FDG-PET or^18^FDG-PET/CT (n= 12), (4) the study provided data for less than 12 participants only (n= 31), (5) the study was not primary research (n = 13), (6) the study was not published in English (n = 21), and (7) the study did not provide separate data for any of the 10 types of cancer considered in the TA (n= 192).

## Excluded – Did not evaluate any of Q1 to Q4 (N = 93)

The following studies were excluded because they did not provide data to evaluate any of the research questions considered in the TA:

### Reference List

1 AlSarraf N, Aziz R, Gately K, et al. Pattern and predictors of occult mediastinal lymph node involvement in non-small cell lung cancer patients with negative mediastinal uptake on positron emission tomography. Eur J Cardiothorac Surg. 2008;33(1):104-9. [pmid: 17977738].
2 Annema JT, Hoekstra OS, Smit EF, et al. Towards a minimally invasive staging strategy in NSCLC: analysis of PET positive mediastinal lesions by EUS-FNA. Lung Cancer. 2004;44(1):53-60. [pmid: 15013583].
3 Aquino SL, Fischman AJ. Does whole-body 2-[18F]-fluoro-2-deoxy-D-glucose positron emission tomography have an advantage over thoracic positron emission tomography for staging patients with lung cancer?. Chest. 2004;126(3):755-60. [pmid: 15364753].
4 Aquino SL, Halpern EF, Kuester LB, et al. FDG-PET and CT features of non-small cell lung cancer based on tumor type. Int J Mol Med. 2007;19(3):495-9. [pmid: 17273799].
5 Ashamalla H, Rafla S, Parikh K, et al. The contribution of integrated PET/CT to the evolving definition of treatment volumes in radiation treatment planning in lung cancer. Int J Radiat Oncol Biol Phys. 2005;63(4):1016-23. [pmid: 15979817].
6 Biehl KJ, Kong FM, Dehdashti F, et al. 18F-FDG-PET definition of gross tumor volume for radiotherapy of non-small cell lung cancer: is a single standardized uptake value threshold approach appropriate?. J Nucl Med. 2006;47(11):1808-12. [pmid: 17079814].
7 Black QC, Grills IS, Kestin LL, et al. Defining a radiotherapy target with positron emission tomography. Int J Radiat Oncol Biol Phys. 2004;60(4):1272-82. [pmid: 15519800].
8 Borst GR, Belderbos JS, Boellaard R, et al. Standardised FDG uptake: a prognostic factor for inoperable non-small cell lung cancer. Eur J Cancer. 2005;41(11):1533-41. [pmid: 15953716].
9 Bosmans G, van Baardwijk A, Dekker A, et al. Intra-patient variability of tumor volume and tumor motion during conventionally fractionated radiotherapy for locally advanced non-small-cell lung cancer: a prospective clinical study. Int J Radiat Oncol Biol Phys. 2006;66(3):748-53. [pmid: 17011450].
10 Bryant AS, Cerfolio RJ. The clinical stage of non-small cell lung cancer as assessed by means of fluorodeoxyglucose-positron emission tomographic/computed tomographic scanning is less accurate in cigarette smokers. J Thorac Cardiovasc Surg. 2006;132(6):1363-8. [pmid: 17140957].
11 Burzynski SR, Janicki TJ, Weaver RA, et al. Targeted therapy with antineoplastons A10 and AS2-1 of high-grade, recurrent, and progressive brainstem glioma. Integr Cancer Ther. 2006;5(1):40-7. [pmid: 16484713].
12 Cerfolio RJ, Bryant AS. Distribution and likelihood of lymph node metastasis based on the lobar location of nonsmall-cell lung cancer. Ann Thorac Surg. 2006;81(6):1969-73. [pmid: 16731115].
13 Cerfolio RJ, Bryant AS. Is palpation of the nonresected pulmonary lobe(s) required for patients with non-small cell lung cancer? A prospective study. J Thorac Cardiovasc Surg. 2008;135(2):261-8. [pmid: 18242247].
14 Cerfolio RJ, Bryant AS, Eloubeidi MA. Accessing the aortopulmonary window (#5) and the paraaortic (#6) lymph nodes in patients with non-small cell lung cancer. Ann Thorac Surg. 2007;84(3):940-5. [pmid: 17720403].
15 Cerfolio RJ, Bryant AS, Ohja B, et al. The maximum standardized uptake values on positron emission tomography of a non-small cell lung cancer predict stage, recurrence, and survival. J Thorac Cardiovasc Surg. 2005;130(1):151-9. [pmid: 15999056].
16 Charnley N, West CM, Barnett CM, et al. Early change in glucose metabolic rate measured using FDG-PET in patients with high-grade glioma predicts response to temozolomide but not temozolomide plus radiotherapy. Int J Radiat Oncol Biol Phys. 2006;66(2):331-8. [pmid: 16839701].
17 Cheran SK, Nielsen ND, Patz EF= Jr. False-negative findings for primary lung tumors on FDG positron emission tomography: staging and prognostic implications. AJR Am J Roentgenol. 2004;182(5):1129-32. [pmid: 15100107].
18 Cherk MH, Foo SS, Poon AM, et al. Lack of correlation of hypoxic cell fraction and angiogenesis with glucose metabolic rate in non-small cell lung cancer assessed by 18F-fluoromisonidazole and 18F-FDG-PET. J Nucl Med. 2006;47(12):1921-6. [pmid: 17138734].
19 Cho SM, Park YG, Lee JM, et al. 18F-fluorodeoxyglucose positron emission tomography in patients with recurrent ovarian cancer: in comparison with vascularity, Ki-67, p53, and histologic grade. Eur Radiol. 2007;17(2):409-17. [pmid: 16786320].
20 Chung JK, Lee YJ, Kim SK, et al. Comparison of [18F]fluorodeoxyglucose uptake with glucose transporter-1 expression and proliferation rate in human glioma and non-small-cell lung cancer. Nucl Med Commun. 2004;25(1):11-7. [pmid: 15061260].
21 de Geus-Oei LF, van Krieken JH, Aliredjo RP, et al. Biological correlates of FDG uptake in non-small cell lung cancer. Lung Cancer. 2007;55(1):79-87. [pmid: 17046099].
22 Dimitrakopoulou-Strauss A, Hoffmann M, Bergner R, et al. Prediction of short-term survival in patients with advanced nonsmall cell lung cancer following chemotherapy based on 2-deoxy-2-[F-18]fluoro-D-glucose-positron emission tomography: a feasibility study. Mol Imaging Biol. 2007;9(5):308-17. [pmid: 17623254].
23 Douglas JG, Stelzer KJ, Mankoff DA, et al. [F18]-fluorodeoxyglucose positron emission tomography for targeting radiation dose escalation for patients with glioblastoma multiforme: clinical outcomes and patterns of failure. Int J Radiat Oncol Biol Phys. 2006;64(3):886-91. [pmid: 16242251].
24 Downey RJ, Akhurst T, Gonen M, et al. Fluorine-18 fluorodeoxyglucose positron emission tomographic maximal standardized uptake value predicts survival independent of clinical but not pathologic TNM staging of resected non-small cell lung cancer. J Thorac Cardiovasc Surg. 2007;133(6):1419-27. [pmid: 17532932].
25 Downey RJ, Akhurst T, Gonen M, et al. Preoperative F-18 fluorodeoxyglucose-positron emission tomography maximal standardized uptake value predicts survival after lung cancer resection. J Clin Oncol. 2004;22(16):3255-60. [pmid: 15310769].
26 Eschmann SM, Friedel G, Paulsen F, et al. Repeat 18F-FDG-PET for monitoring neoadjuvant chemotherapy in patients with stage III non-small cell lung cancer. Lung Cancer. 2007;55(2):165-71. [pmid: 17129635].
27 Freedman NM, Sundaram SK, Kurdziel K, et al. Comparison of SUV and Patlak slope for monitoring of cancer therapy using serial PET scans. Eur J Nucl Med Mol Imaging. 2003;30(1):46-53. [pmid: 12483409].
28 Fricke E, Machtens S, Hofmann M, et al. Positron emission tomography with 11C-acetate and 18F-FDG in prostate cancer patients. Eur J Nucl Med Mol Imaging. 2003;30(4):607-11. [pmid: 12589476].
29 Gagel B, Piroth M, Pinkawa M, et al. Sequential (gemcitabine/vinorelbine) and concurrent (gemcitabine) radiochemotherapy with FDG-PET-based target volume definition in locally advanced non-small cell lung cancer: first results of a phase I/II study. BMC Cancer. 2007;7(112). [doi: 10.1186/14712407-7-112].
30 Gauger J, Patz EF Jr, Coleman RE, et al. Clinical stage I non-small cell lung cancer including FDG-PET Imaging: sites and time to recurrence. J Thorac Oncol. 2007;2(6):499-505. [pmid: 17545844].
31 Grigsby PW, Siegel BA, Dehdashti F, et al. Posttherapy surveillance monitoring of cervical cancer by FDG-PET. Int J Radiat Oncol Biol Phys. 2003;55(4):907-13. [pmid: 12605968].
32 Grigsby PW, Siegel BA, Dehdashti F, et al. Posttherapy [18F] fluorodeoxyglucose positron emission tomography in carcinoma of the cervix: response and outcome. J Clin Oncol. 2004;22(11):2167-71. [pmid: 15169804].
33 Grigsby PW, Singh AK, Siegel BA, et al. Lymph node control in cervical cancer. Int J Radiat Oncol Biol Phys. 2004;59(3):706-12. [pmid: 15183474].
34 Gutman F, Gardin I, Delahaye N, et al. Optimisation of the OS-EM algorithm and comparison with FBP for image reconstruction on a dual-head camera: a phantom and a clinical 18F-FDG study. Eur J Nucl Med Mol Imaging. 2003;30(11):1510-9. [pmid: 14579091].
35 Halpern BS, Dahlbom M, Quon A, et al. Impact of patient weight and emission scan duration on PET/CT image quality and lesion detectability. J Nucl Med. 2004;45(5):797-801. [pmid: 15136629].
36 Hayashi K, Abe K, Sakaguchi C, et al. Questionnaires on mediastinoscopy for mediastinal FDG uptake in patients with non-small cell lung carcinoma; analysis in the institutions without a PET system. Jpn J Clinical Radiol. 2005;50(2):281-3.
37 Helder GJ. Traditional versus up-front 18FDG-PET staging of non-small cell lung cancer (NSCLC): a Dutch Co-operative randomized study. J Clin Oncol. 2004;22(14S):615.
38 Hicks RJ, Mac Manus MP, Matthews JP, et al. Early FDG-PET imaging after radical radiotherapy for non-small-cell lung cancer: inflammatory changes in normal tissues correlate with tumor response and do not confound therapeutic response evaluation. Int J Radiat Oncol Biol Phys. 2004;60(2):412-8. [pmid: 15380574].
39 Higashi K, Ito K, Hiramatsu Y, et al. 18F-FDG uptake by primary tumor as a predictor of intratumoral lymphatic vessel invasion and lymph node involvement in non-small cell lung cancer: analysis of a multicenter study. J Nucl Med. 2005;46(2):267-73. [pmid: 15695786].
40 Huddart RA, O’Doherty MJ, Padhani A, et al. 18fluorodeoxyglucose positron emission tomography in the prediction of relapse in patients with high-risk, clinical stage I nonseminomatous germ cell tumors: preliminary report of MRC Trial TE22--the NCRI Testis Tumour Clinical Study Group. J Clin Oncol. 2007;25(21):3090-5. [pmid: 17634488].
41 Ide M. Cancer screening with FDG-PET. Q J Nucl Med Mol Imaging. 2006;50(1):23-7. [pmid: 16557201].
42 Jaskowiak CJ, Bianco JA, Perlman SB, et al. Influence of reconstruction iterations on [18]F-FDG-PET/CT standardized uptake values. J Nucl Med. 2005;46(3):424-8. [pmid: 15750154].
43 Kajimoto K, Oku N, Kimura Y, et al. Crossed cerebellar diaschisis: a positron emission tomography study with L-[methyl-11C]methionine and 2-deoxy-2-[18F]fluoro-D-glucose. Ann Nucl Med. 2007;21(2):109-13. [pmid: 17424977].
44 Keith CJ, Miles KA, Wong D. Pancreatic cancer: preliminary experience with sodium iodide fluorodeoxyglucose positron emission tomography in Australia. Australas Radiol. 2003;47(1):17-21. [pmid: 12581049].
45 Kidd EA, Siegel BA, Dehdashti F, et al. The standardized uptake value for F-18 fluorodeoxyglucose is a sensitive predictive biomarker for cervical cancer treatment response and survival. Cancer. 2007;110(8):1738-44. [pmid: 17786947].
46 Kim HK, Choi YS, Kim K, et al. Preoperative evaluation of adrenal lesions based on imaging studies and laparoscopic adrenalectomy in patients with otherwise operable lung cancer. Lung Cancer. 2007;58(3):342-7. [pmid: 17825950].
47 Kim S, Chung JK, Im SH, et al. 11C-methionine PET as a prognostic marker in patients with glioma: comparison with 18F-FDG-PET. Eur J Nucl Med Mol Imaging. 2005;32(1):52-9. [pmid: 15309332].
48 Klopp AH, Chang JY, Tucker SL, et al. Intrathoracic patterns of failure for non-small-cell lung cancer with positron-emission tomography/computed tomography-defined target delineation. Int J Radiat Oncol Biol Phys. 2007;69(5):1409-16. [pmid: 17904303].
49 Kong FM, Frey KA, Quint LE, et al. A pilot study of [18F]fluorodeoxyglucose positron emission tomography scans during and after radiation-based therapy in patients with non small-cell lung cancer. J Clin Oncol. 2007;25(21):3116-23. [pmid: 17634490].
50 Koyama K, Okamura T, Kawabe J, et al. Evaluation of 18F-FDG-PET with bladder irrigation in patients with uterine and ovarian tumors. J Nucl Med. 2003;44(3):353-8. [pmid: 12621000].
51 Kruger S, Buck AK, Blumstein NM, et al. Use of integrated FDG-PET/CT imaging in pulmonary carcinoid tumours. J Intern Med. 2006;260(6):545-50. [pmid: 17116005].
52 Kurdziel KA, Figg WD, Carrasquillo JA, et al. Using positron emission tomography 2-deoxy-2-[18F]fluoro-D-glucose, 11CO, and 15O-water for monitoring androgen independent prostate cancer. Mol Imaging Biol. 2003;5(2):86-93. [pmid: 14499149].
53 Kurokawa T, Yoshida Y, Kawahara K, et al. Expression of GLUT-1 glucose transfer, cellular proliferation activity and grade of tumor correlate with [F-18]-fluorodeoxyglucose uptake by positron emission tomography in epithelial tumors of the ovary. Int J Cancer. 2004;109(6):926-32. [pmid: 15027127].
54 Lardinois D, Weder W, Roudas M, et al. Etiology of solitary extrapulmonary positron emission tomography and computed tomography findings in patients with lung cancer. J Clin Oncol. 2005;23(28):6846-53. [pmid: 16192576].
55 Lee JK, Liu RS, Shiang HR, et al. Usefulness of semiquantitative FDG-PET in the prediction of brain tumor treatment response to gamma knife radiosurgery. J Comput Assist Tomogr. 2003;27(4):525-9. [pmid: 12886136].
56 Levivier M, Massager N, Wikler D, et al. Use of stereotactic PET images in dosimetry planning of radiosurgery for brain tumors: clinical experience and proposed classification. J Nucl Med. 2004;45(7):1146-54. [pmid: 15235060].
57 Lindell RM, Hartman TE, Swensen SJ, et al. Lung cancer screening experience: a retrospective review of PET in 22 non-small cell lung carcinomas detected on screening chest CT in a high-risk population. AJR Am J Roentgenol. 2005;185(1):126-31. [pmid: 15972412].
58 Lopez-Rios F, Sanchez-Arago M, Garcia-Garcia E, et al. Loss of the mitochondrial bioenergetic capacity underlies the glucose avidity of carcinomas. Cancer Res. 2007;67(19):9013-7. [pmid: 17909002].
59 Lyshchik A, Higashi T, Hara T, et al. Expression of glucose transporter-1, hexokinase-II, proliferating cell nuclear antigen and survival of patients with pancreatic cancer. Cancer Invest. 2007;25(3):154-62. [pmid: 17530485].
60 Lyshchik A, Higashi T, Nakamoto Y, et al. Dual-phase 18F-fluoro-2-deoxy-D-glucose positron emission tomography as a prognostic parameter in patients with pancreatic cancer. Eur J Nucl Med Mol Imaging. 2005;32(4):389-97. [pmid: 15372209].
61 Mac Manus MP, Hicks RJ, Matthews JP, et al. Positron emission tomography is superior to computed tomography scanning for response-assessment after radical radiotherapy or chemoradiotherapy in patients with non-small-cell lung cancer. J Clin Oncol. 2003;21(7):1285-92. [pmid: 12663716].
62 MacManus MR, Hicks R, Fisher R, et al. FDGPET-detected extracranial metastasis in patients with non-small cell lung cancer undergoing staging for surgery or radical radiotherapy: survival correlates with metastatic disease burden. Acta Oncol. 2003;42(1):48-54. [pmid: 12665331].
63 Menzel C, Dobert N, Hamscho N, et al. The influence of CA 125 and CEA levels on the results of (18)F-deoxyglucose positron emission tomography in suspected recurrence of epithelial ovarian cancer. Strahlenther Onkol. 2004;180(8):497-501. [pmid: 15292970].
64 Meyers BF, Haddad F, Siegel BA, et al. Cost-effectiveness of routine mediastinoscopy in computed tomography- and positron emission tomography-screened patients with stage I lung cancer. J Thorac Cardiovasc Surg. 2006;131(4):822-9. [pmid: 16580440].
65 Miles KA, Griffiths MR, Keith CJ. Blood flow-metabolic relationships are dependent on tumour size in non-small cell lung cancer: a study using quantitative contrast-enhanced computer tomography and positron emission tomography. Eur J Nucl Med Mol Imaging. 2006;33(1):22-8. [pmid: 16180030].
66 Miller TR, Pinkus E, Dehdashti F, et al. Improved prognostic value of 18F-FDG-PET using a simple visual analysis of tumor characteristics in patients with cervical cancer. J Nucl Med. 2003;44(2):192-7. [pmid: 12571208].
67 Morris MJ, Akhurst T, Larson SM, et al. Fluorodeoxyglucose positron emission tomography as an outcome measure for castrate metastatic prostate cancer treated with antimicrotubule chemotherapy. Clin Cancer Res. 2005;11(9):3210-6. [pmid: 15867215].
68 Nahmias C, Hanna WT, Wahl LM, et al. Time course of early response to chemotherapy in non-small cell lung cancer patients with 18F-FDG-PET/CT. J Nucl Med. 2007;48(5):744-51. [pmid: 17475962].
69 Nakamoto Y, Saga T, Higashi T, et al. Optimal scan time for evaluating pancreatic disease with positron emission tomography using F-18-fluorodeoxyglucose. Ann Nucl Med. 2003;17(5):421-6. [pmid: 12971645].
70 Nishizawa S, Inubushi M, Ozawa F, et al. Physiological FDG uptake in the ovaries after hysterectomy. Ann Nucl Med. 2007;21(6):345-8. [pmid: 17705014].
71 Picchio M, Messa C, Landoni C, et al. Value of [11C]choline-positron emission tomography for restaging prostate cancer: a comparison with [18F]fluorodeoxyglucose-positron emission tomography. J Urol. 2003;169(4):1337-40. [pmid: 12629355].
72 Pirotte B, Goldman S, Dewitte O, et al. Integrated positron emission tomography and magnetic resonance imaging-guided resection of brain tumors: a report of 103 consecutive procedures. J Neurosurg. 2006;104(2):238-53. [pmid: 16509498].
73 Pirotte B, Goldman S, Massager N, et al. Comparison of 18F-FDG and 11C-methionine for PET-guided stereotactic brain biopsy of gliomas. J Nucl Med. 2004;45(8):1293-8. [pmid: 15299051].
74 Prevost S, Boucher L, Larivee P, et al. Bone marrow hypermetabolism on 18F-FDG-PET as a survival prognostic factor in non-small cell lung cancer. J Nucl Med. 2006;47(4):559-65. [pmid: 16595487].
75 Qiu JT, Ho KC, Lai CH, et al. Supraclavicular lymph node metastases in cervical cancer. Eur J Gynaecol Oncol. 2007;28(1):33-8. [pmid: 17375703].
76 Risum S, Hogdall C, Loft A, et al. Prediction of suboptimal primary cytoreduction in primary ovarian cancer with combined positron emission tomography/computed tomography--a prospective study. Gynecol Oncol. 2008;108(2):265-70. [pmid: 18055006].
77 Sachs S, Bilfinger TV, Komaroff E, et al. Increased standardized uptake value in the primary lesion predicts nodal or distant metastases at presentation in lung cancer. Clin Lung Cancer. 2005;6(5):310-3. [pmid: 15845183].
78 Schirrmeister H, Arslandemir C, Glatting G, et al. Omission of bone scanning according to staging guidelines leads to futile therapy in non-small cell lung cancer. Eur J Nucl Med Mol Imaging. 2004;31(7):964-8. [pmid: 14991241].
79 Singh AK, Grigsby PW, Dehdashti F, et al. FDG-PET lymph node staging and survival of patients with FIGO stage IIIb cervical carcinoma. Int J Radiat Oncol Biol Phys. 2003;56(2):489-93. [pmid: 12738325].
80 Spence AM, Muzi M, Mankoff DA, et al. 18-FFDG-PET of gliomas at delayed intervals: improved distinction between tumor and normal gray matter. J Nucl Med. 2004;45(10):1653-9. [pmid: 15471829].
81 Sperti C, Pasquali C, Chierichetti F, et al. 18-Fluorodeoxyglucose positron emission tomography in predicting survival of patients with pancreatic carcinoma. J Gastrointest Surg. 2003;7(8):953-60. [pmid: 14675704].
82 Sung J, Espiritu JI, Segall GM, et al. Fluorodeoxyglucose positron emission tomography studies in the diagnosis and staging of clinically advanced prostate cancer. BJU t. 2003;92(1):24-7.
83 Tsai CS, Chang TC, Lai CH, et al. Preliminary report of using FDG-PET to detect extrapelvic lesions in cervical cancer patients with enlarged pelvic lymph nodes on MRI/CT. Int J Radiat Oncol Biol Phys. 2004;58(5):1506-12. [pmid: 15050330].
84 Unger JB, Lilien DL, Caldito G, et al. The prognostic value of pretreatment 2-[18F]-fluoro-2-deoxy-D-glucose positron emission tomography scan in women with cervical cancer. Int J Gynecological Cancer. 2007;17(5):1062-7.
85 van Baardwijk A, Bosmans G, Dekker A, et al. Time trends in the maximal uptake of FDG on PET scan during thoracic radiotherapy. A prospective study in locally advanced non-small cell lung cancer (NSCLC) patients. Radiotherapy Oncol. 2007;82(2):145-52.
86 van Baardwijk A, Dooms C, van Suylen RJ, et al. The maximum uptake of (18)F-deoxyglucose on positron emission tomography scan correlates with survival, hypoxia inducible factor-1alpha and GLUT-1 in non-small cell lung cancer. Eur J Cancer. 2007;43(9):1392-8. [pmid: 17512190].
87 van Der Wel A, Nijsten S, Hochstenbag M, et al. Increased therapeutic ratio by 18FDG-PET CT planning in patients with clinical CT stage N2-N3M0 non-small-cell lung cancer: a modeling study. Int J Radiat Oncol Biol Phys. 2005;61(3):649-55. [pmid: 15708242].
88 Vesselle H, Freeman JD, Wiens L, et al. Fluorodeoxyglucose uptake of primary non-small cell lung cancer at positron emission tomography: new contrary data on prognostic role. Clin Cancer Res. 2007;13(11):3255-63. [pmid: 17545531].
89 Vesselle H, Turcotte E, Wiens L, et al. Relationship between non-small cell lung cancer fluorodeoxyglucose uptake at positron emission tomography and surgical stage with relevance to patient prognosis. Clin Cancer Res. 2004;10(14):4709-16. [pmid: 15269143].
90 Weber WA, Petersen V, Schmidt B, et al. Positron emission tomography in non-small-cell lung cancer: prediction of response to chemotherapy by quantitative assessment of glucose use. J Clin Oncol. 2003;21(14):2651-7. [pmid: 12860940].
91 Yen TC, See LC, Lai CH, et al. 18F-FDG uptake in squamous cell carcinoma of the cervix is correlated with glucose transporter 1 expression. J Nucl Med. 2004;45(1):22-9. [pmid: 14734665].
92 Yokomise H, Gotoh M, Okamoto T, et al. Induction chemoradiotherapy (carboplatin-taxane and concurrent 50-Gy radiation) for bulky cN2, N3 non-small cell lung cancer. J Thorac Cardiovasc Surg. 2007;133(5):1179-85. [pmid: 17467426].
93 Zhang ZJ, Chen JH, Meng L, et al. 18F-FDG uptake as a biologic factor predicting outcome in patients with resected non-small-cell lung cancer. Ch Medical J. 2007;120(2):125-31.

## Excluded – Did not use a matched design (N = 28)

The following studies were excluded because they did not use a matched design:

1 Avril N, Sassen S, Schmalfeldt B, et al. Prediction of response to neoadjuvant chemotherapy by sequential F-18-fluorodeoxyglucose positron emission tomography in patients with advanced-stage ovarian cancer. [erratum appears in J Clin Oncol. 2005 Dec 20;23(36):9445]. J Clin Oncol. 2005;23(30):7445-53. [pmid: 16157939].
2 Borbely K, Nyary I, Toth M, et al. Optimization of semi-quantification in metabolic PET studies with 18F-fluorodeoxyglucose and 11C-methionine in the determination of malignancy of gliomas. J Neurol Sci. 2006;246(1–2):85-94. [pmid: 16603193].
3 Cerfolio RJ, Bryant AS, Eloubeidi MA. Routine mediastinoscopy and esophageal ultrasound fine-needle aspiration in patients with non-small cell lung cancer who are clinically N2 negative: a prospective study. Chest. 2006;130(6):1791-5. [pmid: 17166998].
4 Chen W, Cloughesy T, Kamdar N, et al. Imaging proliferation in brain tumors with 18F-FLT PET: comparison with 18F-FDG. J Nucl Med. 2005;46(6):945-52. [pmid: 15937304].
5 Choi SJ, Kim JS, Kim JH, et al. [18F]3-deoxy3-fluorothymidine PET for the diagnosis and grading of brain tumors. Eur J Nucl Med Mol Imaging. 2005;32(6):653-9. [pmid: 15711980].
6 Cobben DC, Elsinga PH, Hoekstra HJ, et al. Is 18F-3-fluoro-3-deoxy-L-thymidine useful for the staging and restaging of non-small cell lung cancer?. J Nucl Med. 2004;45(10):1677-82. [pmid: 15471832].
7 Conrad GR, Sinha P. Narrow time-window dual-point 18F-FDG-PET for the diagnosis of thoracic malignancy. Nucl Med Commun. 2003;24(11):1129-37. [pmid: 14569166].
8 Fox JL, Rengan R, O’Meara W, et al. Does registration of PET and planning CT images decrease interobserver and intraobserver variation in delineating tumor volumes for non-small-cell lung cancer?. Int J Radiat Oncol Biol Phys. 2005;62(1):70-5. [pmid: 15850904].
9 Hong R, Halama J, Bova D, et al. Correlation of PET standard uptake value and CT window-level thresholds for target delineation in CT-based radiation treatment planning. Int J Radiat Oncol Biol Phys. 2007;67(3):720-6. [pmid: 17293230].
10 Hoopes DJ, Tann M, Fletcher JW, et al. FDG-PET and stereotactic body radiotherapy (SBRT) for stage I non-small-cell lung cancer. Lung Cancer. 2007;56(2):229-34. [pmid: 17353064].
11 Kurosaki H, Oriuchi N, Okazaki A, et al. Prognostic value of FDG-PET in patients with ovarian carcinoma following surgical treatment. Ann Nucl Med. 2006;20(3):171-4. [pmid: 16715946].
12 Lee KH, Lee SH, Kim DW, et al. High fluorodeoxyglucose uptake on positron emission tomography in patients with advanced non-small cell lung cancer on platinum-based combination chemotherapy. Clin Cancer Res. 2006;12(14 Pt 1):4232-6. [pmid: 16857796].
13 Lerman H, Metser U, Grisaru D, et al. Normal and abnormal 18F-FDG endometrial and ovarian uptake in pre- and postmenopausal patients: assessment by PET/CT. J Nucl Med. 2004;45(2):266-71. [pmid: 14960646].
14 Lin LL, Mutic S, Malyapa RS, et al. Sequential FDG-PET brachytherapy treatment planning in carcinoma of the cervix. Int J Radiat Oncol Biol Phys. 2005;63(5):1494-501. [pmid: 16154713].
15 Lin LL, Yang Z, Mutic S, et al. FDG-PET imaging for the assessment of physiologic volume response during radiotherapy in cervix cancer. Int J Radiat Oncol Biol Phys. 2006;65(1):177-81. [pmid: 16545921].
16 Mac Manus MP, Hicks RJ, Matthews JP, et al. Metabolic (FDG-PET) response after radical radiotherapy/chemoradiotherapy for non-small cell lung cancer correlates with patterns of failure. Lung Cancer. 2005;49(1):95-108. [pmid: 15949595].
17 Marom EM, Munden RF, Truong MT, et al. Interobserver and intraobserver variability of standardized uptake value measurements in non-small-cell lung cancer. J Thorac Imaging. 2006;21(3):205-12. [pmid: 16915065].
18 Murakami M, Imahori Y, Kimura S, et al. Positron emission tomography elucidates transport system and tumor proliferation in meningiomas. Oncol Reports. 2005;14(4):853-9.
19 Nestle U, Kremp S, Schaefer-Schuler A, et al. Comparison of different methods for delineation of 18F-FDG-PET-positive tissue for target volume definition in radiotherapy of patients with non-small cell lung cancer. J Nucl Med. 2005;46(8):1342-8. [pmid: 16085592].
20 Pardo FS, Aronen HJ, Fitzek M, et al. Correlation of FDG-PET interpretation with survival in a cohort of glioma patients. Anticancer Res. 2004;24(4):2359-65. [pmid: 15330185].
21 Pirotte B, Goldman S, Massager N, et al. Combined use of 18F-fluorodeoxyglucose and 11C-methionine in 45 positron emission tomography-guided stereotactic brain biopsies. J Neurosurg. 2004;101(3):476-83. [pmid: 15352606].
22 Purcell DD, Coakley FV, Franc BL, et al. Anterior layering of excreted 18F-FDG in the bladder on PET/CT: frequency and cause. AJR Am J Roentgenol. 2007;189(2):W96-9. [pmid: 17646448].
23 Raz DJ, Odisho AY, Franc BL, et al. Tumor fluoro-2-deoxy-D-glucose avidity on positron emission tomographic scan predicts mortality in patients with early-stage pure and mixed bronchioloalveolar carcinoma. J Thorac Cardiovasc Surg. 2006;132(5):1189-95. [pmid: 17059942].
24 Sasaki R, Komaki R, Macapinlac H, et al. [18F]fluorodeoxyglucose uptake by positron emission tomography predicts outcome of non-small-cell lung cancer. J Clin Oncol. 2005;23(6):1136-43. [pmid: 15718309].
25 Schoder H, Erdi YE, Chao K, et al. Clinical implications of different image reconstruction parameters for interpretation of whole-body PET studies in cancer patients. J Nucl Med. 2004;45(4):559-66. [pmid: 15073250].
26 Seemann MD, Schaefer JF, Englmeier KH. Virtual positron emission tomography/computed tomography-bronchoscopy: possibilities, advantages and limitations of clinical application. Eur Radiol. 2007;17(3):709-15. [pmid: 16909219].
27 Seung JC, Jae SK, Jeong HK, et al. [[18]F]3-deoxy-3-fluorothymidine PET for the diagnosis and grading of brain tumors. Eur J Nucl Med Mol Imaging. 2005;32(6):653-9. [pmid: 15711980].
28 Van Laere K, Ceyssens S, Van Calenbergh F, et al. Direct comparison of 18F-FDG and 11C-methionine PET in suspected recurrence of glioma: sensitivity, inter-observer variability and prognostic value. Eur J Nucl Med Mol Imaging. 2005;32(1):39-51. [pmid: 15309329].

## Excluded – Did not use ^18^FDG-PET or ^18^FDG-PET/CT (N = 12)

The following studies were excluded because they did not evaluate the use ^18^FDG-PET or ^18^FDG-PET/CT:

1 Anderson H, Yap JT, Wells P, et al. Measurement of renal tumour and normal tissue perfusion using positron emission tomography in a phase II clinical trial of razoxane. Br J Cancer. 2003;89(2):262-7. [pmid: 12865914].
2 Beuthien-Baumann B, Bredow J, Burchert W, et al. 3-O-methyl-6-[18F]fluoro-L-DOPA and its evaluation in brain tumour imaging. Eur J Nucl Med Mol Imaging. 2003;30(7):1004-8. [pmid: 12768333].
3 Bicher H, Al-Bussam N. Thermoradiotherapy with curative intent: breast, head, neck and prostate tumors. Dtsch Z Onkol. 2006;38(3):116-22.
4 Divgi CR, Pandit-Taskar N, Jungbluth AA, et al. Preoperative characterisation of clear-cell renal carcinoma using iodine-124-labelled antibody chimeric G250 (124I-cG250) and PET in patients with renal masses: a phase I trial. Lancet Oncol. 2007;8(4):304-10. [pmid: 17395103].
5 Halter G, Buck AK, Schirrmeister H, et al. [18F] 3-deoxy-3-fluorothymidine positron emission tomography: alternative or diagnostic adjunct to 2-[18f]-fluoro-2-deoxy-D-glucose positron emission tomography in the workup of suspicious central focal lesions?. J Thorac Cardiovasc Surg. 2004;127(4):1093-9. [pmid: 15052207].
6 Narayan K, McKenzie AF, Hicks RJ, et al. Relation between FIGO stage, primary tumor volume, and presence of lymph node metastases in cervical cancer patients referred for radiotherapy. Int J Gynecological Cancer. 2003;13(5):657-63.
7 Nathoo N, Ugokwe K, Chang AS, et al. The role of 111indium-octreotide brain scintigraphy in the diagnosis of cranial, dural-based meningiomas. J Neuro-Oncol. 2007;81(2):167-74.
8 Nimsky C, Ganslandt O, Buchfelder M, et al. Intraoperative visualization for resection of gliomas: the role of functional neuronavigation and intraoperative 1.5 T MRI. Neurol Res. 2006;28(5):482-7. [pmid: 16808876].
9 Scher B, Seitz M, Albinger W, et al. Value of PET and PET/CT in the diagnostics of prostate and penile cancer. Recent Results Cancer Res. 2008;170:159-79. [pmid: 18019625].
10 Scher B, Seitz M, Albinger W, et al. Value of 11C-choline PET and PET/CT in patients with suspected prostate cancer. Eur J Nucl Med Mol Imaging. 2007;34(1):45-53. [pmid: 16932935].
11 Walker C, du Plessis DG, Fildes D, et al. Correlation of molecular genetics with molecular and morphological imaging in gliomas with an oligodendroglial component. Clin Cancer Res. 2004;10(21):7182-91. [pmid: 15534091].
12 Wallace MB, Block MI, Gillanders W, et al. Accurate molecular detection of non-small cell lung cancer metastases in mediastinal lymph nodes sampled by endoscopic ultrasound-guided needle aspiration. Chest. 2005;127(2):430-7. [pmid: 15705978].

## Excluded – Less than 12 participants (N = 31)

The following studies were excluded because they provided data for less than 12 participants only:

1 Ahmed M, Aslam M, Ahmed J, et al. Renal metastasis from thyroid cancer masquerading as renal angiomyolipoma on ultrasonography. J Ultrasound Med. 2006;25(11):1459-64. [pmid: 17060435].
2 Andrieux A, Switsers O, Chajari MH, et al. Clinical impact of fluorine-18 fluorodeoxyglucose positron emission tomography in cancer patients. A comparative study between dedicated camera and dual-head coincidence gamma camera. Q J Nucl Med Mol Imaging. 2006;50(1):68-71. [pmid: 16557206].
3 Anjos DA, Etchebehere EC, Ramos C, et al. 18F-FDG-PET/CT delayed images after diuretic for restaging invasive bladder cancer. J Nucl Med. 2007;48(5):764-70. [pmid: 17475965].
4 Buchmann I, Vogg ATJ, Glatting G, et al. [18-F]5-fluoro-2-deoxyuridine-PET for imaging of malignant tumors and for measuring tissue proliferation. Cancer Biother Radiopharm. 2003;18(3):327-37. [pmid: 12954120].
5 Cwikla JB, Nasierowska-Guttmejer A, Jeziorski KG, et al. Diagnostic imaging approach to gastro-entero-pancreatic carcinomas of neuroendocrine origin: single NET center experience in Poland. Neuroendocrinol Lett. 2007;28(6):789-800. [pmid: 18063942].
6 De Pas TM, de Braud F, Catalano G, et al. Oligometastatic non-small cell lung cancer: a multidisciplinary approach in the positron emission tomographic scan era. Ann Thorac Surg. 2007;83(1):231-4. [pmid: 17184669].
7 Donaldson MJ, Pulido JS, Mullan BP, et al. Combined positron emission tomography/computed tomography for evaluation of presumed choroidal metastases. Clin Exp Ophthalmol. 2006;34(9):846-51.
8 Eloubeidi MA, Cerfolio RJ, Chen VK, et al. Endoscopic ultrasound-guided fine needle aspiration of mediastinal lymph node in patients with suspected lung cancer after positron emission tomography and computed tomography scans. Ann Thorac Surg. 2005;79(1):263-8. [pmid: 15620955].
9 EvenSapir E, Lerman H, Gutman M, et al. The presentation of malignant tumours and pre-malignant lesions incidentally found on PET-CT. Eur J Nucl Med Mol Imaging. 2006;33(5):541-52. [pmid: 16491423].
10 Garcia JR, Simo M, Huguet M, et al. Usefulness of 18-fluorodeoxyglucose positron emission tomography in the evaluation of tumor cardiac thrombus from renal cell carcinoma. Clin Transl Oncol. 2006;8(2):124-8. [pmid: 16632427].
11 Goerres GW, Burger C, Schwitter MR, et al. PET/CT of the abdomen: optimizing the patient breathing pattern. Eur Radiol. 2003;13(4):734-9. [pmid: 12664111].
12 Gulec SA, Hoenie E, Hostetter R, et al. PET probe-guided surgery: applications and clinical protocol. World J Surg Oncol. 2007;5(65). [doi: 10.1186/1477-7819-5-65].
13 Holloway CL, Robinson D, Murray B, et al. Results of a phase I study to dose escalate using intensity modulated radiotherapy guided by combined PET/CT imaging with induction chemotherapy for patients with non-small cell lung cancer. Radiotherapy Oncol. 2004;73(3):285-7.
14 Hustinx R, Lemaire C, Jerusalem G, et al. Whole-body tumor imaging using PET and 2-18Ffluoro-L-tyrosine: preliminary evaluation and comparison with 18F-FDG. J Nucl Med. 2003;44(4):533-9. [pmid: 12679396].
15 Langen KJ, Hamacher K, Pauleit D, et al. Evaluation of new 18F-labeled amino acids for brain PET. Anat Embryol. 2005;210(5–6):455-61. [pmid: 16177907].
16 Murakami M, Imahori Y, Kimura S, et al. Positron emission tomography elucidates transport system and tumor proliferation in meningiomas. Oncol Reports. 2005;14(4):853-9.
17 Nestle U, Schaefer-Schuler A, Kremp S, et al. Target volume definition for 18F-FDG-PET-positive lymph nodes in radiotherapy of patients with non-small cell lung cancer. Eur J Nucl Med Mol Imaging. 2007;34(4):453-62. [pmid: 17058078].
18 Osman MM, Cohade C, Fishman EK, et al. Clinically significant incidental findings on the unenhanced CT portion of PET/CT studies: frequency in 250 patients. J Nucl Med. 2005;46(8):1352-5. [pmid: 16085594].
19 Pauleit D, Stoffels G, Schaden W, et al. PET with O-(2-18F-Fluoroethyl)-L-Tyrosine in peripheral tumors: first clinical results. J Nucl Med. 2005;46(3):411-6. [pmid: 15750152].
20 Pinker K, Noebauer-Huhmann IM, Stavrou I, et al. High-resolution contrast-enhanced, susceptibility-weighted MR imaging at 3T in patients with brain tumors: correlation with positron-emission tomography and histopathologic findings. Am J Neuroradiol. 2007;28(7):1280-6. [pmid: 17698528].
21 Schneider BJ, Avram AM, Shulkin BL, et al. False-positive findings with positron emission tomography in the staging of non-small-cell lung cancer. Clin Adv Hematol Oncol. 2005;3(7):571-3. [pmid: 16167039].
22 Strong VE, Humm J, Russo P, et al. A novel method to localize antibody-targeted cancer deposits intraoperatively using handheld PET beta and gamma probes. Surg Endoscopy. 2008;22(2):386-91.
23 Sung YM, Lee KS, Kim BT, et al. Nonpalpable supraclavicular lymph nodes in lung cancer patients: preoperative characterization with 18F-FDG-PET/CT. AJR Am J Roentgenol. 2008;190(1):246-52. [pmid: 18094319].
24 Tann M, Sandrasegaran K, Jennings SG, et al. Positron-emission tomography and computed tomography of cystic pancreatic masses. Clin Radiol. 2007;62(8):745-51. [pmid: 17604762].
25 Thie JA, Smith GT, Hubner KF. 2-deoxy-2-[F-18]fluoro-D-glucose-positron emission tomography sensitivity to serum glucose: a survey and diagnostic applications. Mol Imaging Biol. 2005;7(5):361-8. [pmid: 16228119].
26 Tian M, Zhang H, Higuchi T, et al. Oncological diagnosis using (11)C-choline-positron emission tomography in comparison with 2-deoxy-2-[(18)F] fluoro-D-glucose-positron emission tomography. Mol Imaging Biol. 2004;6(3):172-9. [pmid: 15193251].
27 Tian M, Zhang H, Oriuchi N, et al. Comparison of 11C-choline PET and FDG-PET for the differential diagnosis of malignant tumors. Eur J Nucl Med Mol Imaging. 2004;31(8):1064-72. [pmid: 15014903].
28 Tillmanns T, Lowe MP. Safety, feasibility, and costs of outpatient laparoscopic extraperitoneal aortic nodal dissection for locally advanced cervical carcinoma. Gynecol Oncol. 2007;106(2):370-4. [pmid: 17509671].
29 Torizuka T, Kanno T, Futatsubashi M, et al. Imaging of gynecologic tumors: comparison of (11)C-choline PET with (18)F-FDG-PET. J Nucl Med. 2003;44(7):1051-6. [pmid: 12843219].
30 Wang F, Wang Z, Yao W, et al. Role of 99mTc-octreotide acetate scintigraphy in suspected lung cancer compared with 18F-FDG dual-head coincidence imaging. J Nucl Med. 2007;48(9):1442-8. [pmid: 17704242].
31 Yi JG, Marom EM, Munden RF, et al. Focal uptake of fluorodeoxyglucose by the thyroid in patients undergoing initial disease staging with combined PET/CT for non-small cell lung cancer. Radiology. 2005;236(1):271-5. [pmid: 15987980].

## Excluded – Not primary research (N = 13)

The following studies were excluded because they were not primary research:

1 Anonymous. Notice of correction: results of ACOSOG Z0050 trial: the utility of FDG-PET in staging potentially operable non-small cell lung cancer. J Thorac Cardiovasc Surg. 2007;133(4):864.
2 Avril N. Erratum: prediction of response to neoadjuvant chemotherapy by sequential F-18-fluorodeoxyglucose positron emission tomography in patients with advanced-stage ovarian cancer (Journal of Clinical Oncology (October 20, 2005) 23 (7445-7453)). J Clin Oncol. 2005;23(36):9445.
3 Bujenovic S. The role of positron emission tomography in radiation treatment planning. Sem Nucl Med. 2004;34(4):293-9.
4 Calculli L, Pezzilli R, Casadei R, et al. The imaging of pancreatic exocrine solid tumors: the role of computed tomography and positron emission tomography. JOP. 2007;8(Suppl 1):77-84. [pmid: 17228139].
5 DeGrendele H, Belani CP, Naumann R, et al. Fluorodeoxyglucose positron emission tomography as a staging and prognostic tool in non-small-cell lung cancer. Clin Lung Cancer. 2003;4(4):213-6. [pmid: 14624708].
6 Eschmann SM, Friedel G, Paulsen F, et al. Erratum: is standardised 18F-FDG uptake value an outcome predictor in patients with stage III non-small cell lung cancer?. (European Journal of Nuclear Medicine and Molecular Imaging (2006) 33 (389) DOI: 10.1007/s00259-005-1953-2). Eur J Nucl Med Mol Imaging. 2006;33(3):389.
7 Irshad A, Ravenel JG. Imaging of small-cell lung cancer. Curr Probl Diagn Radiol. 2004;33(5):200-11. [pmid: 15459630].
8 Kernstine KH. Positron emission tomography with 2-[18f]fluoro-2-deoxy-D-glucose: can it be used to accurately stage the mediastinum in non-small cell lung cancer as an alternative to mediastinoscopy?. [comment]. J Thorac Cardiovasc Surg. 2003;126(6):1700-3. [pmid: 14688674].
9 Konety B. 11C-acetate positron emission tomography imaging and image fusion with computed tomography and magnetic resonance imaging in patients with recurrent prostate cancer. Urol Oncol. 2007;25(1):90.
10 Miller JC, Fischman AJ, Aquino SL, et al. FDG-PET CT for tumor imaging. JACR. 2007;4(4):256-9. [pmid: 17412280].
11 Schmid RA, Hautmann H, Poellinger B, et al. Staging of recurrent and advanced lung cancer with 18F-FDG-PET in a coincidence technique (hybrid PET). Nucl Med Commun. 2003;24(1):37-45. [pmid: 12501018].
12 Sloka JS, Hollett PD. Cost effectiveness of positron emission tomography in Canada. Med Sci Monit. 2005;11(10):PH1-6. [pmid: 16192911].
13 Viney RC, Boyer MJ, King MT, et al. Staging lung cancer using positron emission tomography and the impact on care. J Clin Outcome Manag. 2004;11(8):486-8.

## Excluded – Non-English publications (N = 21)

The following studies were excluded because they were not published in English:

1 Ai B, Pan T, Zheng Z, et al. The relationship of expression of GLUT1, HIF-1alpha and the uptake of FDG in non-small cell lung cancer. Ch J Lung Cancer. 2007;10(6):508-12.
2 Fujino M, Taguchi T, Kato T, et al. Utilization the fusion image of CT and FDG-PET for radiation therapy planning in lung cancer. Jpn J Clinical Radiol. 2007;52(1):137-44.
3 He S, Guan Y, Zhao J. The effect of standardized uptake value of[18]F-FDG-PET on prognosis of non-small cell lung cancer. Ch J Clin Oncol. 2006;33(3):167-70.
4 Kawada S, Suzuki Y, Hinohara S, et al. Cancer screening with PET: advantages and limitations. Rinsho Byori. 2007;55(7):656-67. [pmid: 17718062].
5 Kawamoto K, Nakagawa M, Jinnouchi S. Possibilities of FDG-PET in diagnosis of urological tumors. Nishihon J Urol. 2004;66(5):386-92.
6 Kim GH, Jo MK, Cheon GJ, et al. Clinical role of F-18 fluorodeoxyglucose positron emission tomography for follow-up of patients with renal cell carcinoma. KJU. 2007;48(8):765-70.
7 Li Q, Tan T. The application of 18F-FDG-PET in diagnosis and treatment of pancreatic cancer. Ch J Clin Oncol. 2006;33(5):296-9.
8 Li SQ, Huang C, Liu HS, et al. Value of PET examination in preoperative diagnosis of lymph node metastasis in the patients with NSCLC. Ch J Cancer Prev Treat. 2007;14(6):452-3.
9 Nakayama Y, Kitamoto Y, Ishikawa H, et al. Comparison between positron emission tomography and computed tomography in the use of the assessment of lung cancer after radical radiotherapy. Jpn J Clinical Radiol. 2005;50(1):155-60.
10 Provencio M, Sanchez A, Gonzalez C, et al. PET and PET-CT in the staging and treatment of non-small cell lung cancer. Oncologia. 2007;30(3):28-40.
11 Sasaki R, Okamoto Y, Sugimura K. Efficacy of FDG-PET in patients with lung cancer and esophageal cancer. Jpn J Clinical Radiol. 2007;52(8):985-91.
12 Schultze J, Both M, Lutzen U. Aspects of imaging in radiation oncology with special reference to brachytherapy. Nowotwory. 2007;57(4):376-82.
13 Seto T, Goto K. FDG-PET in non-small cell lung cancer. Respir Circul. 2003;51(9):935-8.
14 Talbot JN, Montravers F, Grahek D, et al. FDG-PET and its impact on patient’s management in oncology. Presse Med. 2006;35(9II):1339-46. [pmid: 16969330].
15 Umeoka S, Saga T, Togashi K, et al. The role of FDG-PET in the management of lung cancer. Respir Circul. 2005;53(6):613-8.
16 Wang X, Yu LJ. [18]F-FDG-PET/CT in detection of pancreatic cancer: value of synthetic analysis interpretation. Ch J Med Imag Technol. 2007;23(11):1709-12.
17 Wang Y, Zhou Q. PET in the diagnosis and treatment of lung cancer. Ch J Lung Cancer. 2003;6(6):418-22.
18 Wu Z, Zhang YX, Wei H, et al. The role of whole body 2-[fluorine-18]-fluoro-2-deoxy-D-glucose positron emission tomography/computed tomography in the management of unknown primary tumors. Nat Med J China. 2007;87(32):2253-6.
19 Xu B, Liu Y, Yao S, et al. Value of FDG-PET for mediastinal lymph node staging in non-small cell lung cancer. Ch J Lung Cancer. 2003;6(3):198-200.
20 Yu LJ, Duan Y, Liang XY, et al. [18]F-FDG-PET/CT in diagnosis and metastasis detection of lung neoplasms. Ch J Med Imag Technol. 2007;23(4):605-7.
21 Zhang YB, Zhu JR, Kang JB, et al. Application of [18]F-FDG coincidence/CT imaging in stereotactic radiotherapy of non-small cell lung cancer. Ch J Med Imag Technol. 2006;22(3):455-7.

## Excluded – Not on any of the nine types of cancer (N = 192)

The following studies were excluded because they did not provide separate data for any of the nine types of cancer considered in the TA:

1 Abe K, Kosuda S, Kusano S. Medical economics of whole-body FDG-PET in patients suspected of having non-small cell lung carcinoma: reassessment based on the revised Japanese national insurance reimbursement system. Ann Nucl Med. 2003;17(8):649-55. [pmid: 14971606].
2 Akeboshi M, Yamakado K, Nakatsuka A, et al. Percutaneous radiofrequency ablation of lung neoplasms: initial therapeutic response. J Vasc Interv Radiol. 2004;15(5):463-70. [pmid: 15126656].
3 Al-Sarraf N, Aziz R, Doddakula K, et al. Factors causing inaccurate staging of mediastinal nodal involvement in non-small cell lung cancer patients staged by positron emission tomography. Interact Cardiovas Thorac Surg. 2007;6(3):350-3.
4 Al-Sarraf N, Gately K, Lucey J, et al. Mediastinal lymph node staging by means of positron emission tomography is less sensitive in elderly patients with non-small-cell lung cancer. Clin Lung Cancer. 2008;9(1):39-43. [pmid: 18282357].
5 Alzahouri K, Lejeune C, Woronoff-Lemsi MC, et al. Cost-effectiveness analysis of strategies introducing FDG-PET into the mediastinal staging of non-small-cell lung cancer from the French healthcare system perspective. Clin Radiol. 2005;60(4):479-92. [pmid: 15767106].
6 Ambrosini V, Nanni C, Rubello D, et al. 18F-FDG-PET/CT in the assessment of carcinoma of unknown primary origin. Radiol Med. 2006;111(8):1146-5. [pmid: 17171520].
7 Anderson HL, Yap JT, Miller MP, et al. Assessment of pharmacodynamic vascular response in a phase I trial of combretastatin A4 phosphate. J Clin Oncol. 2003;21(15):2823-30. [pmid: 12807935].
8 Antoch G, Stattaus J, Nemat AT, et al. Non-small cell lung cancer: dual-modality PET/CT in preoperative staging. Radiology. 2003;229(2):526-33. [pmid: 14512512].
9 Aquino SL, Asmuth JC, Alpert NM, et al. Improved radiologic staging of lung cancer with 2-[18F]-fluoro-2-deoxy-D-glucose-positron emission tomography and computed tomography registration. J Comput Assist Tomogr. 2003;27(4):479-84. [pmid: 12886128].
10 Au Yong TK, Wong CP, Leung YK, et al. Evaluation of positron-emission tomography in the diagnosis of primary tumours in patients presenting with metastases: prospective study. J Hong Kong Coll Radiol. 2005;8(1):9-14.
11 Bastarrika G, Garcia-Velloso MJ, Lozano MD, et al. Early lung cancer detection using spiral computed tomography and positron emission tomography. Am J Respir Crit Care Med. 2005;171(12):1378-83. [pmid: 15790860].
12 Bastiaannet E, Oyen WJG, Meijer S, et al. Impact of [18F]fluorodeoxyglucose positron emission tomography on surgical management of melanoma patients. Br J Surg. 2006;93(2):243-9. [pmid: 16323165].
13 Beer AJ, Lorenzen S, Metz S, et al. Comparison of integrin alphaVbeta3 expression and glucose metabolism in primary and metastatic lesions in cancer patients: a PET study using 18F-galacto-RGD and 18F-FDG. J Nucl Med. 2008;49(1):22-9. [pmid: 18077538].
14 Belohlavek O, Simonova G, Kantorova I, et al. Brain metastases after stereotactic radiosurgery using the Leksell gamma knife: can FDG-PET help to differentiate radionecrosis from tumour progression?. Eur J Nucl Med Mol Imaging. 2003;30(1):96-100. [pmid: 12483415].
15 Bernasconi M, Chhajed PN, Gambazzi F, et al. Combined transbronchial needle aspiration and positron emission tomography for mediastinal staging of NSCLC. Eur Respir J. 2006;27(5):889-94. [pmid: 16455825].
16 Berner U, Menzel C, Rinne D, et al. Paraneoplastic syndromes: detection of malignant tumors using [[18]F]FDG-PET. Q J Nucl Med. 2003;47(2):85-9. [pmid: 12865868].
17 Berthelsen AK, Holm S, Loft A, et al. PET/CT with intravenous contrast can be used for PET attenuation correction in cancer patients. Eur J Nucl Med Mol Imaging. 2005;32(10):1167-75. [pmid: 15909196].
18 Bradley J, Thorstad WL, Mutic S, et al. Impact of FDG-PET on radiation therapy volume delineation in non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2004;59(1):78-86. [pmid: 15093902].
19 Brechtel K, Klein M, Vogel M, et al. Optimized contrast-enhanced CT protocols for diagnostic whole-body 18F-FDG-PET/CT: technical aspects of single-phase versus multiphase CT imaging. J Nucl Med. 2006;47(3):470-6. [pmid: 16513616].
20 Brianzoni E, Rossi G, Ancidei S, et al. Radiotherapy planning: PET/CT scanner performances in the definition of gross tumour volume and clinical target volume. [erratum appears in Eur J Nucl Med Mol Imaging. 2005 Dec;32(12):1491 Note: algranati, Carlo [added]]. Eur J Nucl Med Mol Imaging. 2005;32(12):1392-9. [pmid: 16133395].
21 Bruzzi JF, Truong MT, Marom EM, et al. Incidental findings on integrated PET/CT that do not accumulate 18F-FDG. [erratum appears in AJR Am J Roentgenol. 2007 Feb;188(2):300]. AJR Am J Roentgenol. 2006;187(4):1116-23. [pmid: 16985164].
22 Bryant AS, Cerfolio RJ. The maximum standardized uptake values on integrated FDG-PET/CT is useful in differentiating benign from malignant pulmonary nodules. Ann Thorac Surg. 2006;82(3):1016-20. [pmid: 16928527].
23 Buck AK, Halter G, Schirrmeister H, et al. Imaging proliferation in lung tumors with PET: 18F-FLT versus 18F-FDG. J Nucl Med. 2003;44(9):1426-31. [pmid: 12960187].
24 Buck AK, Hetzel M, Schirrmeister H, et al. Clinical relevance of imaging proliferative activity in lung nodules. Eur J Nucl Med Mol Imaging. 2005;32(5):525-33. [pmid: 15599526].
25 Ceresoli GL, Cattaneo GM, Castellone P, et al. Role of computed tomography and [18F] fluorodeoxyglucose positron emission tomography image fusion in conformal radiotherapy of non-small cell lung cancer: a comparison with standard techniques with and without elective nodal irradiation. Tumori. 2007;93(1):88-96. [pmid: 17455878].
26 Cerfolio RJ, Bryant AS. Predictors of survival and disease-free survival in patients with resected N1 non-small cell lung cancer. Ann Thorac Surg. 2007;84(1):182-90. [pmid: 17588408].
27 Cerfolio RJ, Bryant AS. Ratio of the maximum standardized uptake value on FDG-PET of the mediastinal (N2) lymph nodes to the primary tumor may be a universal predictor of nodal malignancy in patients with nonsmall-cell lung cancer. Ann Thorac Surg. 2007;83(5):1826-30. [pmid: 17462407].
28 Cerfolio RJ, Bryant AS. When is it best to repeat a 2-fluoro-2-deoxy-D-glucose positron emission tomography/computed tomography scan on patients with non-small cell lung cancer who have received neoadjuvant chemoradiotherapy?. Ann Thorac Surg. 2007;84(4):1092-7. [pmid: 17888953].
29 Cerfolio RJ, Bryant AS, Ojha B. Restaging patients with N2 (stage IIIa) non-small cell lung cancer after neoadjuvant chemoradiotherapy: a prospective study. [erratum appears in J Thorac Cardiovasc Surg. 2006 Sep;132(3):565-7]. J Thorac Cardiovasc Surg. 2006;131(6):1229-35. [pmid: 16733150].
30 Cerfolio RJ, Bryant AS, Ojha B, et al. Improving the inaccuracies of clinical staging of patients with NSCLC: a prospective trial. Ann Thorac Surg. 2005;80(4):1207-4. [pmid: 16181842].
31 Cerfolio RJ, Bryant AS, Winokur TS, et al. Repeat FDG-PET after neoadjuvant therapy is a predictor of pathologic response in patients with non-small cell lung cancer. Ann Thorac Surg. 2004;78(6):1903-9. [pmid: 15560998].
32 Cerfolio RJ, Ojha B, Bryant AS, et al. The role of FDG-PET scan in staging patients with nonsmall cell carcinoma. Ann Thorac Surg. 2003;76(3):861-6. [pmid: 12963217].
33 Cerfolio RJ, Ojha B, Bryant AS, et al. The accuracy of integrated PET-CT compared with dedicated PET alone for the staging of patients with nonsmall cell lung cancer. Ann Thorac Surg. 2004;78(3):1017-23. [pmid: 15337041].
34 Cerfolio RJ, Ojha B, Mukherjee S, et al. Positron emission tomography scanning with 2-fluoro2-deoxy-d-glucose as a predictor of response of neoadjuvant treatment for non-small cell carcinoma. J Thorac Cardiovasc Surg. 2003;125(4):938-44. [pmid: 12698159].
35 Chen LB, Tong JL, Song HZ, et al. 18-F-DG PET/CT in detection of recurrence and metastasis of colorectal cancer. World J Gastroenterol. 2007;13(37):5025-9. [pmid: 17854148].
36 Chen YK, Ding HJ, Su CT, et al. Application of PET and PET/CT imaging for cancer screening. Anticancer Res. 2004;24(6):4103-8. [pmid: 15736459].
37 Chen YK, Kao CH, Liao AC, et al. Colorectal Cancer Screening in Asymptomatic Adults: the Role of FDG-PET Scan. Anticancer Res. 2003;23(5B):4357-61. [pmid: 14666651].
38 Cheran SK, Herndon JE 2nd, Patz EF Jr. Comparison of whole-body FDG-PET to bone scan for detection of bone metastases in patients with a new diagnosis of lung cancer. Lung Cancer. 2004;44(3):317-25. [pmid: 15140545].
39 Choi JY, Lee KS, Kwon OJ, et al. Improved detection of second primary cancer using integrated [[18]F] fluorodeoxyglucose positron emission tomography and computed tomography for initial tumor staging. J Clin Oncol. 2005;23(30):7654-9. [pmid: 16234527].
40 Chong S, Lee KS, Kim BT, et al. Integrated PET/CT of pulmonary neuroendocrine tumors: diagnostic and prognostic implications. AJR Am J Roentgenol. 2007;188(5):1223-31. [pmid: 17449764].
41 Chung JH, Lee WW, Park SY, et al. FDG uptake and glucose transporter type 1 expression in lymph nodes of non-small cell lung cancer. Eur J Surg Oncol. 2006;32(9):989-95. [pmid: 16859874].
42 Craanen ME, Comans EF, Paul MA, et al. Endoscopic ultrasound guided fine-needle aspiration and 18FDG-positron emission tomography in the evaluation of patients with non-small cell lung cancer. Interact Cardiovas Thorac Surg. 2007;6(4):433-6.
43 Daniels CE, Lowe VJ, Aubry MC, et al. The utility of fluorodeoxyglucose positron emission tomography in the evaluation of carcinoid tumors presenting as pulmonary nodules. Chest. 2007;131(1):255-60. [pmid: 17218584].
44 de Geus-Oei LF, van der Heijden HF, Visser EP, et al. Chemotherapy response evaluation with 18F-FDG-PET in patients with non-small cell lung cancer. J Nucl Med. 2007;48(10):1592-8. [pmid: 17873138].
45 De Leyn P, Stroobants S, De Wever W, et al. Prospective comparative study of integrated positron emission tomography-computed tomography scan compared with remediastinoscopy in the assessment of residual mediastinal lymph node disease after induction chemotherapy for mediastinoscopy-proven stage IIIA-N2 Non-small-cell lung cancer: a Leuven Lung Cancer Group Study. J Clin Oncol. 2006;24(21):3333-9. [pmid: 16849747].
46 De Ruysscher D, Wanders S, Minken A, et al. Effects of radiotherapy planning with a dedicated combined PET-CT-simulator of patients with non-small cell lung cancer on dose limiting normal tissues and radiation dose-escalation: a planning study. Radiotherapy Oncol. 2005;77(1):5-10.
47 De Ruysscher D, Wanders S, van Haren E, et al. Selective mediastinal node irradiation based on FDG-PET scan data in patients with non-small-cell lung cancer: a prospective clinical study. Int J Radiat Oncol Biol Phys. 2005;62(4):988-94. [pmid: 15989999].
48 De Santis M, Becherer A, Bokemeyer C, et al. 2-18fluoro-deoxy-D-glucose positron emission tomography is a reliable predictor for viable tumor in postchemotherapy seminoma: an update of the prospective multicentric SEMPET trial. J Clin Oncol. 2004;22(6):1034-9. [pmid: 15020605].
49 Delahaye N, Crestani B, Rakotonirina H, et al. Comparative impact of standard approach, FDG-PET and FDG dual-head coincidence gamma camera imaging in preoperative staging of patients with nonsmall-cell lung cancer. Nucl Med Commun. 2003;24(12):1215-24. [pmid: 14627847].
50 Downey RJ, Akhurst T, Gonen M, et al. Preoperative F-18 fluorodeoxyglucose-positron emission tomography maximal standardized uptake value predicts survival after lung cancer resection. J Clin Oncol. 2004;22(16):3255-60. [pmid: 15310769].
51 Ebihara A, Nomori H, Watanabe K, et al. Characteristics of advantages of positron emission tomography over computed tomography for N-staging in lung cancer patients. Jpn J Clin Oncol. 2006;36(11):694-8. [pmid: 17068084].
52 Eloubeidi MA, Tamhane A, Chen VK, et al. Endoscopic ultrasound-guided fine-needle aspiration in patients with non-small cell lung cancer and prior negative mediastinoscopy. Ann Thorac Surg. 2005;80(4):1231-9. [pmid: 16181845].
53 Eschmann SM, Bitzer M, Paulsen F, et al. The benefit of functional-anatomical imaging with [18F]fluorodeoxyglucose utilizing a dual-head coincidence gamma camera with an integrated X-ray transmission system in non-small cell lung cancer. Nucl Med Commun. 2004;25(9):909-15. [pmid: 15319596].
54 Eschmann SM, Friedel G, Paulsen F, et al. Repeat [18]F-FDG-PET for monitoring neoadjuvant chemotherapy in patients with stage III non-small cell lung cancer. Lung Cancer. 2007;55(2):165-71. [pmid: 17129635].
55 Eschmann SM, Friedel G, Paulsen F, et al. 18F-FDG-PET for assessment of therapy response and preoperative re-evaluation after neoadjuvant radio-chemotherapy in stage III non-small cell lung cancer. Eur J Nucl Med Mol Imaging. 2007;34(4):463-71. [pmid: 17103167].
56 Eschmann SM, Friedel G, Paulsen F, et al. Is standardised (18)F-FDG uptake value an outcome predictor in patients with stage III non-small cell lung cancer?. [erratum appears in Eur J Nucl Med Mol Imaging. 2006 Mar;33(3):389]. Eur J Nucl Med Mol Imaging. 2006;33(3):263-9. [pmid: 16270214].
57 Eschmann SM, Friedel G, Paulsen F, et al. Impact of staging with 18F-FDG-PET on outcome of patients with stage III non-small cell lung cancer: PET identifies potential survivors. Eur J Nucl Med Mol Imaging. 2007;34(1):54-9. [pmid: 16896660].
58 Ferran N, Ricart Y, Lopez M, et al. Characterization of radiologically indeterminate lung lesions: 99mTc-depreotide SPECT versus 18F-FDG-PET. Nucl Med Commun. 2006;27(6):507-14. [pmid: 16710105].
59 Fletcher JW, Kymes SM, Gould M, et al. A comparison of the diagnostic accuracy of [18]F-FDG-PET and CT in the characterization of solitary pulmonary nodules. J Nucl Med. 2008;49(2):179-85. [pmid: 18199626].
60 Fogarty GB, Peters LJ, Stewart J, et al. The usefulness of fluorine 18-labelled deoxyglucose positron emission tomography in the investigation of patients with cervical lymphadenopathy from an unknown primary tumor. Head Neck. 2003;25(2):138-45. [pmid: 12509797].
61 Fritscher-Ravens A, Bohuslavizki KH, Brandt L, et al. Mediastinal lymph node involvement in potentially resectable lung cancer: comparison of CT, positron emission tomography, and endoscopic ultrasonography with and without fine-needle aspiration. Chest. 2003;123(2):442-51. [pmid: 12576364].
62 Giammarile F, Cinotti LE, Jouvet A, et al. High and low grade oligodendrogliomas (ODG): correlation of amino-acid and glucose uptakes using PET and histological classifications. J Neuro-Oncol. 2004;68(3):263-74.
63 Gollub MJ, Hong R, Sarasohn DM, et al. Limitations of CT during PET/CT. J Nucl Med. 2007;48(10):1583-91. [pmid: 17873133].
64 Gondi V, Bradley K, Mehta M, et al. Impact of hybrid fluorodeoxyglucose positron-emission tomography/computed tomography on radiotherapy planning in esophageal and non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 2007;67(1):187-95. [pmid: 17189070].
65 Gonzalez-Stawinski GV, Lemaire A, Merchant F, et al. A comparative analysis of positron emission tomography and mediastinoscopy in staging non-small cell lung cancer. J Thorac Cardiovasc Surg. 2003;126(6):1900-5. [pmid: 14688703].
66 Gugiatti A, Grimaldi A, Rossetti C, et al. Economic analyses on the use of positron emission tomography for the work-up of solitary pulmonary nodules and for staging patients with non-small-celllung-cancer in Italy. Q J Nucl Med Mol Imaging. 2004;48(1):49-61. [pmid: 15195004].
67 Guntinas-Lichius O, Klussmann JP, Dinh S, et al. Diagnostic work-up and outcome of cervical metastases from an unknown primary. Acta Otolaryngol. 2006;126(5):536-44. [pmid: 16698706].
68 Gururangan S, Hwang E, Herndon JE 2nd, et al. [18F]fluorodeoxyglucose-positron emission tomography in patients with medulloblastoma. Neurosurg. 2004;55(6):1280-9.
69 Gutzeit A, Antoch G, Kuhl H, et al. Unknown primary tumors: detection with dual-modality PET/CT. Initial experience. Radiology. 2005;234(1):227-34. [pmid: 15564390].
70 Halpern BS, Schiepers C, Weber WA, et al. Presurgical staging of non-small cell lung cancer: positron emission tomography, integrated positron emission tomography/CT, and software image fusion. Chest. 2005;128(4):2289-97. [pmid: 16236886].
71 Halter G, Buck AK, Schirrmeister H, et al. Lymph node staging in lung cancer using [18F]FDG-PET. Thorac Cardiovasc Surg. 2004;52(2):96-101. [pmid: 15103582].
72 Harris MT, Berlangieri SU, Cebon JS, et al. Impact of 2-Deoxy-2[F-18]Fluoro-D-Glucose positron emission tomography on the management of patients with advanced melanoma. Mol Imaging Biol. 2006;7(4):304-8. [pmid: 16041590].
73 Hayashi K, Abe K, Yano F, et al. Should mediastinoscopy actually be incorporated into the FDG-PET strategy for patients with non-small cell lung carcinoma?. Ann Nucl Med. 2005;19(5):393-8. [pmid: 16164196].
74 Hellwig D, Graeter TP, Ukena D, et al. Value of F-18-fluorodeoxyglucose positron emission tomography after induction therapy of locally advanced bronchogenic carcinoma. J Thorac Cardiovasc Surg. 2004;128(6):892-9. [pmid: 15573074].
75 Hellwig D, Graeter TP, Ukena D, et al. 18F-FDG-PET for mediastinal staging of lung cancer: which SUV threshold makes sense?. J Nucl Med. 2007;48(11):1761-6. [pmid: 17942814].
76 Hellwig D, Groschel A, Graeter TP, et al. Diagnostic performance and prognostic impact of FDG-PET in suspected recurrence of surgically treated non-small cell lung cancer. Eur J Nucl Med Mol Imaging. 2006;33(1):13-21. [pmid: 16151765].
77 Herder GJ, Golding RP, Hoekstra OS, et al. The performance of [18]F-fluorodeoxyglucose positron emission tomography in small solitary pulmonary nodules. Eur J Nucl Med Mol Imaging. 2004;31(9):1231-6. [pmid: 15175835].
78 Herder GJ, Kramer H, Hoekstra OS, et al. Traditional versus up-front [18F] fluorodeoxyglucose-positron emission tomography staging of non-small-cell lung cancer: a Dutch cooperative randomized study. J Clin Oncol. 2006;24(12):1800-6. [pmid: 16567772].
79 Herder GJ, Van Tinteren H, Comans EF, et al. Prospective use of serial questionnaires to evaluate the therapeutic efficacy of 18F-fluorodeoxyglucose (FDG) positron emission tomography (PET) in suspected lung cancer. Thorax. 2003;58(1):47-51. [pmid: 12511720].
80 Hillner BE, Siegel BA, Liu D, et al. Impact of positron emission tomography/computed tomography and positron emission tomography (PET) alone on expected management of patients with cancer: initial results from the national oncologic PET registry. J Clin Oncol. 2008;26(13):2155-61. [pmid: 18362365].
81 Hillner BE, Tunuguntla R, Fratkin M. Clinical decisions associated with positron emission tomography in a prospective cohort of patients with suspected or known cancer at one United States center. J Clinical Oncol. 2004;22(20):4147-56. [pmid: 15483025].
82 Hoekstra CJ, Stroobants SG, Hoekstra OS, et al. The value of [18F]fluoro-2-deoxy-D-glucose positron emission tomography in the selection of patients with stage IIIA-N2 non-small cell lung cancer for combined modality treatment. Lung Cancer. 2003;39(2):151-7. [pmid: 12581567].
83 Hoekstra CJ, Stroobants SG, Smit EF, et al. Prognostic relevance of response evaluation using [18F]-2-fluoro-2-deoxy-D-glucose positron emission tomography in patients with locally advanced nonsmall-cell lung cancer. J Clin Oncol. 2005;23(33):8362-70. [pmid: 16293866].
84 Horowitz NS, Dehdashti F, Herzog TJ, et al. Prospective evaluation of FDG-PET for detecting pelvic and para-aortic lymph node metastasis in uterine corpus cancer. Gynecol Oncol. 2004;95(3):546-51. [pmid: 15581961].
85 Hsu LH, Ko JS, You DL, et al. Transbronchial needle aspiration accurately diagnoses subcentimetre mediastinal and hilar lymph nodes detected by integrated positron emission tomography and computed tomography. Respirology. 2007;12(6):848-55. [pmid: 17986113].
86 Husain A, Akhurst T, Larson S, et al. A prospective study of the accuracy of 18Fluorodeoxyglucose positron emission tomography (18FDG-PET) in identifying sites of metastasis prior to pelvic exenteration. Gynecol Oncol. 2007;106(1):177-80. [pmid: 17477959].
87 Iagaru A, Masamed R, Singer PA, et al. Detection of occult medullary thyroid cancer recurrence with 2-deoxy-2-[F-18]fluoro-D-glucose-PET and PET/CT. Mol Imaging Biol. 2007;9(2):72-7. [pmid: 17186139].
88 Ishimori T, Patel PV, Wahl RL. Detection of unexpected additional primary malignancies with PET/CT. J Nucl Med. 2005;46(5):752-7. [pmid: 15872346].
89 Israel O, Mor M, Guralnik L, et al. Is 18F-FDG-PET/CT useful for imaging and management of patients with suspected occult recurrence of cancer?. J Nucl Med. 2004;45(12):20.45-51.
90 Joo HO, Ie RY, Sung HK, et al. Clinical significance of small pulmonary nodules with little or no [18]F-FDG uptake on PET/CT images of patients with nonthoracic malignancies. J Nucl Med. 2007;48(1):15-21. [pmid: 17204694].
91 Kahn D, Menda Y, Kernstine K, et al. The utility of 99mTc depreotide compared with F-18 fluorodeoxyglucose positron emission tomography and surgical staging in patients with suspected non-small cell lung cancer. Chest. 2004;125(2):494-501. [pmid: 14769730].
92 Kaira K, Oriuchi N, Otani Y, et al. Fluorine-18-alpha-methyltyrosine positron emission tomography for diagnosis and staging of lung cancer: a clinicopathologic study. Clin Cancer Res. 2007;13(21):6369-78. [pmid: 17975149].
93 Kamel EM, Jichlinski P, Prior JO, et al. Forced diuresis improves the diagnostic accuracy of 18F-FDG-PET in abdominopelvic malignancies. J Nucl Med. 2006;47(11):1803-7. [pmid: 17079813].
94 Kanegae K, Nakano I, Kimura K, et al. Comparison of MET-PET and FDG-PET for differentiation between benign lesions and lung cancer in pneumoconiosis. Ann Nucl Med. 2007;21(6):331-7. [pmid: 17705012].
95 Keidar Z, Haim N, Guralnik L, et al. PET/CT using 18F-FDG in suspected lung cancer recurrence: diagnostic value and impact on patient management. J Nucl Med. 2004;45(10):1640-6. [pmid: 15471827].
96 Kelly RF, Tran T, Holmstrom A, et al. Accuracy and cost-effectiveness of [18F]-2-fluorodeoxy-D-glucose-positron emission tomography scan in potentially resectable non-small cell lung cancer. Chest. 2004;125(4):1413-23. [pmid: 15078754].
97 Khan N, Oriuchi N, Zhang H, et al. A comparative study of 11C-choline PET and [18F]fluorodeoxyglucose PET in the evaluation of lung cancer. Nucl Med Commun. 2003;24(4):359-66. [pmid: 12673163].
98 Kim BT, Lee KS, Shim SS, et al. Stage T1 non-small cell lung cancer: preoperative mediastinal nodal staging with integrated FDG-PET/CT: a prospective study. Radiology. 2006;241(2):501-9. [pmid: 16966480].
99 Kim SK, Allen-Auerbach M, Goldin J, et al. Accuracy of PET/CT in characterization of solitary pulmonary lesions. J Nucl Med. 2007;48(2):214-20. [pmid: 17268017].
100 Kim YK, Lee KS, Kim BT, et al. Mediastinal nodal staging of nonsmall cell lung cancer using integrated 18F-FDG-PET/CT in a tuberculosis-endemic country: diagnostic efficacy in 674 patients. Cancer. 2007;109(6):1068-77. [pmid: 17311309].
101 Konishi J, Yamazaki K, Tsukamoto E, et al. Mediastinal lymph node staging by FDG-PET in patients with non-small cell lung cancer: analysis of false-positive FDG-PET findings. Respiration. 2003;70(5):500-6. [pmid: 14665776].
102 Koshy M, Paulino AC, Howell R, et al. F-18 FDG-PET-CT fusion in radiotherapy treatment planning for head and neck cancer. Head Neck. 2005;27(6):494-502. [pmid: 15772951].
103 Kramer H, Post WJ, Pruim J, et al. The prognostic value of positron emission tomography in non-small cell lung cancer: analysis of 266 cases. Lung Cancer. 2006;52(2):213-7. [pmid: 16545488].
104 Kuker RA, Mesoloras G, Gulec SA. Optimization of FDG-PET/CT imaging protocol for evaluation of patients with primary and metastatic liver disease. Int Sem Surg Oncol. 2007;4(17). [doi: 10.1186/1477-7800-4-17].
105 Kula Z, Pietrzak T, Malkowski B. Initial evaluation of combined positron emission tomography and computed tomography by using [18]F-fluorodeoxyglucose in gastroenteropancreatic neuroendocrine tumor patients. Gastroenterol Pol. 2006;13(5):349-53.
106 Kunkel M, Reichert TE, Benz P, et al. Overexpression of Glut-1 and increased glucose metabolism in tumors are associated with a poor prognosis in patients with oral squamous cell carcinoma. Cancer. 2003;97(4):1015-24. [pmid: 12569601].
107 Kurli M, Reddy S, Tena LB, et al. Whole body positron emission tomography/computed tomography staging of metastatic choroidal melanoma. Am J Ophthalmol. 2005;140(2):193.e1-193.e9. [pmid: 15992753].
108 Laffon E, Vialard J, Allard M, et al. Feasibility of an SUV normalization to 1 hour after the 18F-FDG injection. C R Biol. 2006;329(7):520-6. [pmid: 16797458].
109 Lardinois D, Weder W, Hany TF, et al. Staging of non-small-cell lung cancer with integrated positron-emission tomography and computed tomography. New Engl J Med. 2003;348(25):2500-7. [pmid: 12815135].
110 Lee BE, Redwine J, Foster C, et al. Mediastinoscopy might not be necessary in patients with non-small cell lung cancer with mediastinal lymph nodes having a maximum standardized uptake value of less than 5.3. J Thorac Cardiovasc Surg. 2008;135(3):615-9. [pmid: 18329480].
111 Lee BE, von Haag D, Lown T, et al. Advances in positron emission tomography technology have increased the need for surgical staging in non-small cell lung cancer. J Thorac Cardiovasc Surg. 2007;133(3):746-52. [pmid: 17320577].
112 Lee ST, Berlangieri SU, Poon AMT, et al. Prevalence of occult metastatic disease in patients undergoing [18]F-FDG-PET for primary diagnosis or staging of lung carcinoma and solitary pulmonary nodules. Intern Med J. 2007;37(11):753-9. [pmid: 17517082].
113 Lee WW, Chung JH, Jang SJ, et al. Consideration of serum glucose levels during malignant mediastinal lymph node detection in nonsmall-cell lung cancer by FDG-PET. J Surg Oncol. 2006;94(7):607-13. [pmid: 17039492].
114 Levivier M, Massager N, Wikler D, et al. Integration of functional imaging in radiosurgery: the example of PET scan. Prog Neurol Surg. 2007;20:68-81. [pmid: 17317977].
115 Levivier M, Massager N, Wikler D, et al. Modern multimodal neuroimaging for radiosurgery: the example of PET scan integration. Acta Neurochir. Suppl 91. 2004:1-7. [pmid: 14740259].
116 Lewandowska A, Windorbska W, Morgas T. Radiation treatment planning using positron emission tomography for patients with non-small cell lung cancer. Nowotwory. 2006;56(3):259-64. +. 309. 14.
117 Linke R, Schroeder M, Helmberger T, et al. Antibody-positive paraneoplastic neurologic syndromes: value of CT and PET for tumor diagnosis. Neurology. 2004;63(2):282-6. [pmid: 15277621].
118 Lodge MA, Badawi RD, Gilbert R, et al. Comparison of 2-dimensional and 3-dimensional acquisition for 18F-FDG-PET oncology studies performed on an LSO-based scanner. J Nucl Med. 2006;47(1):23-31. [pmid: 16391183].
119 Low SY, Eng P, Keng GH, et al. Positron emission tomography with CT in the evaluation of non-small cell lung cancer in populations with a high prevalence of tuberculosis. Respirology. 2006;11(1):84-9. [pmid: 16423207].
120 Mamede M, Higashi T, Kitaichi M, et al. [[18]F]FDG uptake and PCNA, Glut-1, and Hexokinase-II expressions in cancers and inflammatory lesions of the lung. Neoplasia. 2005;7(4):369-79. [pmid: 15967114].
121 Melek H, Gunluoglu MZ, Demir A, et al. Role of positron emission tomography in mediastinal lymphatic staging of non-small cell lung cancer. Eur J Cardiothorac Surg. 2008;33(2):294-9. [pmid: 18096398].
122 Messa C, Ceresoli GL, Rizzo G, et al. Feasibility of [18F]FDG-PET and coregistered CT on clinical target volume definition of advanced non-small cell lung cancer. Q J Nucl Med Mol Imaging. 2005;49(3):259-66. [pmid: 16172572].
123 Miller FR, Hussey D, Beeram M, et al. Positron emission tomography in the management of unknown primary head and neck carcinoma. Arch Otolaryngol Head Neck Surg. 2005;131(7):626-9. [pmid: 16027287].
124 Minamimoto R, Senda M, Uno K, et al. Performance profile of FDG-PET and PET/CT for cancer screening on the basis of a Japanese Nationwide Survey. Ann Nucl Med. 2007;21(9):481-98. [pmid: 18030580].
125 Minn H, Salonen A, Friberg J, et al. Imaging of adrenal incidentalomas with PET using (11)C-metomidate and (18)F-FDG. J Nucl Med. 2004;45(6):972-9. [pmid: 15181132].
126 Nagaoka S, Itano S, Ishibashi M, et al. Value of fusing PET plus CT images in hepatocellular carcinoma and combined hepatocellular and cholangiocarcinoma patients with extrahepatic metastases: preliminary findings. Liver Int. 2006;26(7):781-8. [pmid: 16911459].
127 Nakamoto Y, Osman M, Wahl RL. Prevalence and patterns of bone metastases detected with positron emission tomography using F-18 FDG. Clin Nucl Med. 2003;28(4):302-7. [pmid: 12642709].
128 Nakamoto Y, Sakamoto S, Okada T, et al. Accuracy of image fusion using a fixation device for whole-body cancer imaging. AJR Am J Roentgenol. 2005;184(6):1960-6. [pmid: 15908562].
129 Narin Y, Urhan M, Canpolat N, et al. Lesion detectability and clinical effectiveness of dual-head coincidence gamma camera imaging in comparison with dedicated PET systems in tumour patients. J Int Med Res. 2007;35(4):467-73. [pmid: 17697523].
130 Nassenstein K, Veit-Haibach P, Stergar H, et al. Cervical lymph node metastases of unknown origin: primary tumor detection with whole-body positron emission tomography/computed tomography. Acta Radiol. 2007;48(10):1101-8. [pmid: 17963088].
131 Nguyen VH, Peloquin S, Lacasse Y. Cost-effectiveness of positron emission tomography for the management of potentially operable non-small cell lung cancer in Quebec. Can Respir J. 2005;12(1):19-25. [pmid: 15776130].
132 Nomori H, Kosaka N, Watanabe K, et al. 11C-acetate positron emission tomography imaging for lung adenocarcinoma 1 to 3 cm in size with ground-glass opacity images on computed tomography. Ann Thorac Surg. 2005;80(6):2020-5. [pmid: 16305837].
133 Nomori H, Watanabe K, Ohtsuka T, et al. Evaluation of F-18 fluorodeoxyglucose (FDG) PET scanning for pulmonary nodules less than 3 cm in diameter, with special reference to the CT images. Lung Cancer. 2004;45(1):19-27. [pmid: 15196730].
134 Nomori H, Watanabe K, Ohtsuka T, et al. The size of metastatic foci and lymph nodes yielding false-negative and false-positive lymph node staging with positron emission tomography in patients with lung cancer. J Thorac Cardiovasc Surg. 2004;127(4):1087-92. [pmid: 15052206].
135 Nomori H, Watanabe K, Ohtsuka T, et al. Visual and semiquantitative analyses for F-18 fluorodeoxyglucose PET scanning in pulmonary nodules 1 cm to 3 cm in size. Ann Thorac Surg. 2005;79(3):984-8. [pmid: 15734419].
136 Ohtsuka T, Nomori H, Ebihara A, et al. FDG-PET imaging for lymph node staging and pathologic tumor response after neoadjuvant treatment of non-small cell lung cancer. Ann Thoracic Cardiovasc Surg. 2006;12(2):89-94.
137 Ono K, Ochiai R, Yoshida T, et al. The detection rates and tumor clinical/pathological stages of whole-body FDG-PET cancer screening. Ann Nucl Med. 2007;21(1):65-72. [pmid: 17373338].
138 Oturai PS, Mortensen J, Enevoldsen H, et al. Gamma-camera [18]F-FDG-PET in diagnosis and staging of patients presenting with suspected lung cancer and comparison with dedicated PET. J Nucl Med. 2004;45(8):1351-7. [pmid: 15299061].
139 Paulsen F, Scheiderbauer J, Eschmann SM, et al. First experiences of radiation treatment planning with PET/CT. Strahlenther Onkol. 2006;182(7):369-75. [pmid: 16826354].
140 Pelosi E, Pennone M, Deandreis D, et al. Role of whole body positron emission tomography/computed tomography scan with [18]F-fluorodeoxyglucose in patients with biopsy proven tumor metastases from unknown primary site. Q J Nucl Med Mol Imaging. 2006;50(1):15-22. [pmid: 16557200].
141 Pfannenberg AC, Aschoff P, Brechtel K, et al. Low dose non-enhanced CT versus standard dose contrast-enhanced CT in combined PET/CT protocols for staging and therapy planning in non-small cell lung cancer. Eur J Nucl Med Mol Imaging. 2007;34(1):36-44. [pmid: 16896664].
142 Pfannenberg C, Aschoff P, Schanz S, et al. Prospective comparison of [18]F-fluorodeoxyglucose positron emission tomography/computed tomography and whole-body magnetic resonance imaging in staging of advanced malignant melanoma. Eur J Cancer. 2007;43(3):557-64. [pmid: 17224266].
143 Picchio M, Savi A, Lecchi M, et al. Evaluation of the clinical performances of a large NaI(Tl) crystal 3D PET scanner. Q J Nucl Med. 2003;47(2):90-100. [pmid: 12865869].
144 Port JL, Andrade RS, Levin MA, et al. Positron emission tomographic scanning in the diagnosis and staging of non-small cell lung cancer 2 cm in size or less. J Thorac Cardiovasc Surg. 2005;130(6):1611-5. [pmid: 16308006].
145 Port JL, Kent MS, Korst RJ, et al. Positron emission tomography scanning poorly predicts response to preoperative chemotherapy in non-small cell lung cancer. Ann Thorac Surg. 2004;77(1):254-9. [pmid: 14726072].
146 Posther KE, McCall LM, Harpole DH Jr, et al. Yield of brain 18F-FDG-PET in evaluating patients with potentially operable non-small cell lung cancer. J Nucl Med. 2006;47(10):1607-11. [pmid: 17015895].
147 Pottgen C, Levegrun S, Theegarten D, et al. Value of 18F-fluoro-2-deoxy-D-glucose-positron emission tomography/computed tomography in nonsmall-cell lung cancer for prediction of pathologic response and times to relapse after neoadjuvant chemoradiotherapy. Clin Cancer Res. 2006;12(1):97-106. [pmid: 16397030].
148 Pozo-Rodriguez F, Martin de Nicolas JL, Sanchez-Nistal MA, et al. Accuracy of helical computed tomography and [18F] fluorodeoxyglucose positron emission tomography for identifying lymph node mediastinal metastases in potentially resectable non-small-cell lung cancer. J Clin Oncol. 2005;23(33):8348-56. [pmid: 16219937].
149 Quon A, Napel S, Beaulieu CF, et al. “Flying through” and “flying around” a PET/CT scan: pilot study and development of 3D integrated 18F-FDG-PET/CT for virtual bronchoscopy and colonoscopy. J Nucl Med. 2006;47(7):1081-7. [pmid: 16818940].
150 Reed CE, Harpole DH, Posther KE, et al. Results of the American College of Surgeons Oncology Group Z0050 trial: the utility of positron emission tomography in staging potentially operable non-small cell lung cancer. [erratum appears in J Thorac Cardiovasc Surg. 2007 Apr;133(4):864]. J Thorac Cardiovasc Surg. 2003;126(6):1943-51. [pmid: 14688710].
151 Reinhardt MJ, Wiethoelter N, Matthies A, et al. PET recognition of pulmonary metastases on PET/CT imaging: impact of attenuation-corrected and non-attenuation-corrected PET images. Eur J Nucl Med Mol Imaging. 2006;33(2):134-9. [pmid: 16193313].
152 Rodriguez Fernandez A, Gomez Rio M, Llamas Elvira JM, et al. Diagnosis efficacy of structural (CT) and functional (FDG-PET) imaging methods in the thoracic and extrathoracic staging of non-small cell lung cancer. Clin Transl Oncol. 2007;9(1):32-9. [pmid: 17272228].
153 Rohren EM, Provenzale JM, Barboriak DP, et al. Screening for cerebral metastases with FDG-PET in patients undergoing whole-body staging of non-central nervous system malignancy. Radiology. 2003;226(1):181-7. [pmid: 12511688].
154 Schaffler GJ, Wolf G, Schoellnast H, et al. Non-small cell lung cancer: evaluation of pleural abnormalities on CT scans with 18F FDG-PET. Radiology. 2004;231(3):858-65. [pmid: 15105451].
155 Schmidt GP, BaurMelnyk A, Herzog P, et al. High-resolution whole-body magnetic resonance image tumor staging with the use of parallel imaging versus dual-modality positron emission tomography-computed tomography: experience on a 32-channel system. Invest Radiol. 2005;40(12):743-53. [pmid: 16304476].
156 Schmucking M, Baum RP, Griesinger F, et al. Molecular whole-body cancer staging using positron emission tomography: consequences for therapeutic management and metabolic radiation treatment planning. Recent Results Cancer Res. 2006;162:195-202. [pmid: 12790335].
157 Scott CL, Kudaba I, Stewart JM, et al. The utility of 2-deoxy-2-[F-18]fluoro-D-glucose positron emission tomography in the investigation of patients with disseminated carcinoma of unknown primary origin. Mol Imaging Biol. 2005;7(3):236-43. [pmid: 15912428].
158 Shen YY, Su CT, Chen GJ, et al. The value of 18F-fluorodeoxyglucose positron emission tomography with the additional help of tumor markers in cancer screening. Neoplasma. 2003;50(3):217-21. [pmid: 12937856].
159 Shim SS, Lee KS, Kim BT, et al. Non-small cell lung cancer: prospective comparison of integrated FDG-PET/CT and CT alone for preoperative staging. Radiology. 2005;236(3):1011-9. [pmid: 16014441].
160 Singer E, Gschwantler M, Plattner D, et al. Differential diagnosis of benign and malign pancreatic masses with 18F-fluordeoxyglucose-positron emission tomography recorded with a dual-head coincidence gamma camera. Eur J Gastroenterol Hepatol. 2007;19(6):471-8. [pmid: 17489057].
161 Sloka JS, Hollett PD, Mathews M. Cost-effectiveness of positron emission tomography for non-small cell lung carcinoma in Canada. Med Sci Monit. 2004;10(5):MT73-80. [pmid: 15114279].
162 Solberg TD, Agazaryan N, Goss BW, et al. A feasibility study of 18F-fluorodeoxyglucose positron emission tomography targeting and simultaneous integrated boost for intensity-modulated radiosurgery and radiotherapy. J Neurosurg. 2004;101(Suppl 3):381-9. [pmid: 15537193].
163 Souvatzoglou M, Ziegler SI, Martinez MJ, et al. Standardised uptake values from PET/CT images: comparison with conventional attenuation-corrected PET. Eur J Nucl Med Mol Imaging. 2007;34(3):405-12. [pmid: 16953402].
164 Spaggiari L, Sverzellati N, Versari A, et al. Evaluation of N parameter in the staging of non-small cell lung cancer: role of CT and PET. Radiol Med. 2005;109(5–6):449-59. [pmid: 15973219].
165 Sperti C, Pasquali C, Decet G, et al. F-18-fluorodeoxyglucose positron emission tomography in differentiating malignant from benign pancreatic cysts: a prospective study. J Gastrointest Surg. 2005;9(1):22-9. [pmid: 15623441].
166 Sperti C, Pasquali C, Fiore V, et al. Clinical usefulness of 18-fluorodeoxyglucose positron emission tomography in the management of patients with nonpancreatic periampullary neoplasms. Am J Surgery. 2006;191(6):743-8.
167 Stevens H, Bakker PF, Schlosser NJ, et al. Use of a dual-head coincidence camera and 18F-FDG for detection and nodal staging of non-small cell lung cancer: accuracy as determined by 2 independent observers. J Nucl Med. 2003;44(3):336-40. [pmid: 12620997].
168 Stoeckli SJ, Mosna-Firlejczyk K, Goerres GW. Lymph node metastasis of squamous cell carcinoma from an unknown primary: impact of positron emission tomography. Eur J Nucl Med Mol Imaging. 2003;30(3):411-6. [pmid: 12634970].
169 Stroobants SG, D’Hoore I, Dooms C, et al. Additional value of whole-body fluorodeoxyglucose positron emission tomography in the detection of distant metastases of non-small-cell lung cancer. Clin Lung Cancer. 2003;4(4):242-7. [pmid: 14624714].
170 Sugiyama M, Sakahara H, Torizuka T, et al. [18]F-FDG-PET in the detection of extrahepatic metastases from hepatocellular carcinoma. J Gastroenterol. 2004;39(10):961-8. [pmid: 15549449].
171 Suzuki A, Kawano T, Takahashi N, et al. Value of [18]F-FDG-PET in the detection of peritoneal carcinomatosis. Eur J Nucl Med Mol Imaging. 2004;31(10):1413-20. [pmid: 15205922].
172 Takamochi K, Yoshida J, Murakami K, et al. Pitfalls in lymph node staging with positron emission tomography in non-small cell lung cancer patients. Lung Cancer. 2005;47(2):235-42. [pmid: 15639722].
173 Tournoy KG, Maddens S, Gosselin R, et al. Integrated FDG-PET/CT does not make invasive staging of the intrathoracic lymph nodes in non-small cell lung cancer redundant: a prospective study. Thorax. 2007;62(8):696-701. [pmid: 17687098].
174 Tsunezuka Y, Shimizu Y, Tanaka N, et al. Positron emission tomography in relation to Noguchi’s classification for diagnosis of peripheral non-small-cell lung cancer 2 cm or less in size. World J Surg. 2007;31(2):314-7. [pmid: 17219276].
175 Turkmen C, Sonmezoglu K, Toker A, et al. The additional value of FDG-PET imaging for distinguishing N0 or N1 from N2 stage in preoperative staging of non-small cell lung cancer in region where the prevalence of inflammatory lung disease is high. Clin Nucl Med. 2007;32(8):607-12. [pmid: 17667432].
176 Turlakow A, Yeung HW, Salmon AS, et al. Peritoneal carcinomatosis: role of (18)F-FDG-PET. J Nucl Med. 2003;44(9):1407-12. [pmid: 12960184].
177 Verboom P, van Tinteren H, Hoekstra OS, et al. Cost-effectiveness of FDG-PET in staging non-small cell lung cancer: the PLUS study. Eur J Nucl Med Mol Imaging. 2003;30(11):1444-9. [pmid: 14579081].
178 Viney RC, Boyer MJ, King MT, et al. Randomized controlled trial of the role of positron emission tomography in the management of stage I and II non-small-cell lung cancer. J Clin Oncol. 2004;22(12):2357-62. [pmid: 15197196].
179 Wakabayashi H, Akamoto S, Yachida S, et al. Significance of fluorodeoxyglucose PET imaging in the diagnosis of malignancies in patients with biliary stricture. Eur J Surg Oncol. 2005;31(10):1175-9. [pmid: 16019182].
180 Wang SX, Boethius J, Ericson K. FDG-PET on irradiated brain tumor: ten years’ summary. Acta Radiol. 2006;47(1):85-90. [pmid: 16498938].
181 Wartski M, Stanc EL, Gontier E, et al. In search of an unknown primary tumour presenting with cervical metastases: performance of hybrid FDG-PET-CT. Nucl Med Commun. 2007;28(5):365-71. [pmid: 17414886].
182 Wever W, Ceyssens S, Mortelmans L, et al. Additional value of PET-CT in the staging of lung cancer: comparison with CT alone, PET alone and visual correlation of PET and CT. Eur Radiol. 2007;17(1):23-32. [pmid: 16683115].
183 Yamamoto Y, Nishiyama Y, Ishikawa S, et al. Correlation of 18F-FLT and 18F-FDG uptake on PET with Ki-67 immunohistochemistry in non-small cell lung cancer. Eur J Nucl Med Mol Imaging. 2007;34(10):1610-6. [pmid: 17530250].
184 Yamamoto Y, Nishiyama Y, Kimura N, et al. Comparison of [18]F-FLT PET and [18]F-FDG-PET for preoperative staging in non-small cell lung cancer. Eur J Nucl Med Mol Imaging. 2008;35(2):236-45. [pmid: 17909790].
185 Yamamoto Y, Nishiyama Y, Monden T, et al. Correlation of FDG-PET findings with histopathology in the assessment of response to induction chemoradiotherapy in non-small cell lung cancer. Eur J Nucl Med Mol Imaging. 2006;33(2):140-7. [pmid: 16220306].
186 Yanagawa T, Watanabe H, Inoue T, et al. Carbon-11 choline positron emission tomography in musculoskeletal tumors: comparison with fluorine-18 fluorodeoxyglucose positron emission tomography. J Comput Assist Tomogr. 2003;27(2):175-82. [pmid: 12703009].
187 Yap CS, Czernin J, Fishbein MC, et al. Evaluation of thoracic tumors with 18F-fluorothymidine and 18F-fluorodeoxyglucose-positron emission tomography. Chest. 2006;129(2):393-401. [pmid: 16478857].
188 Yap KK, Yap KS, Byrne AJ, et al. Positron emission tomography with selected mediastinoscopy compared to routine mediastinoscopy offers cost and clinical outcome benefits for pre-operative staging of non-small cell lung cancer. Eur J Nucl Med Mol Imaging. 2005;32(9):1033-40. [pmid: 15875178].
189 Yi CA, Lee KS, Kim BT, et al. Efficacy of helical dynamic CT versus integrated PET/CT for detection of mediastinal nodal metastasis in non-small cell lung cancer. AJR Am J Roentgenol. 2007;188(2):318-25. [pmid: 17242237].
190 Zanation AM, Sutton DK, Couch ME, et al. Use, accuracy, and implications for patient management of [18F]-2-fluorodeoxyglucose-positron emission/computerized tomography for head and neck tumors. Laryngoscope. 2005;115(7):1186-90. [pmid: 15995504].
191 Zettinig G, Mitterhauser M, Wadsak W, et al. Positron emission tomography imaging of adrenal masses: (18)F-fluorodeoxyglucose and the 11beta-hydroxylase tracer (11)C-metomidate. Eur J Nucl Med Mol Imaging. 2004;31(9):1224-30. [pmid: 15197504].
192 Zissin R, Metser U, Hain D, et al. Mesenteric panniculitis in oncologic patients: PET-CT findings. Br J Radiol. 2006;79(937):37-43. [pmid: 16421403].