# TA Forms

B1 Title and Abstract Screening Form

B2 Eligibility Criteria Form

B3 Methodological Quality Assessment Forms

B4 Data Extraction Forms