# Search strategies

## Electronic Searches: Exact Search Strings

### Databases searched for relevant studies

Database | Years/issues | Date of search
MEDLINE^®^ | 2002 - 2008 | 12 March, 2008
EMBASE | 2002 - 2008 | 12 March, 2008
CENTRAL (Cochrane Central Register of Controlled Trials, NHS Economic Evaluation Database) | 1rst Quarter 2008 | 20 March, 2008
Scopus | 2002-2008 | 19 March, 2008

### Table A1 MEDLINE® - Ovid Version

Years/issue searched: 2002 to 2008

Search date: 12 March, 2008

#### Bladder cancer

1. exp Tomography, Emission-Computed/
2. positron$.mp.
3. pet.mp.
4. emission compute$ tomography.mp.
5. Fluorodeoxyglucose F18/
6. fdg.mp.
7. fluorodeoxyglucose.mp.
8. or/1-7
9. (bladder adj3 (cancer$ or neopla$ or tumor$ or tumour$ or carcino$)).mp.
10. 8 and 9
11. limit 10 to yr="2002 - 2008"

#### Brain cancer

1. exp Tomography, Emission-Computed/
2. positron$.mp.
3. pet.mp.
4. emission compute$ tomography.mp.
5. Fluorodeoxyglucose F18/
6. fdg.mp.
7. fluorodeoxyglucose.mp.
8. or/1-7
9. exp Brain Neoplasms/
10. (brain adj3 (cancer$ or neoplasm$ or tumor$ or tumour$ or carcino$)).mp.
11. (glioblastoma$ or astrocytoma$ or oligodendroglioma$).mp.
12. or/9-11
13. 8 and 12
14. limit 13 to yr="2002 - 2008"

#### Cervical cancer

1. exp Tomography, Emission-Computed/
2. positron$.mp.
3. pet.mp.
4. emission compute$ tomography.mp.
5. Fluorodeoxyglucose F18/
6. fdg.mp.
7. fluorodeoxyglucose.mp.
8. or/1-7
9. Uterine Cervical Neoplasms/
10. Uterine Cervical Dysplasia/
11. Cervical Intraepithelial Neoplasia/
12. or/9-11
13. Cervix Uteri/
14. (cancer or neoplas$ or dysplas$ or carcinoma$ or tumor$ or tumour$).mp.
15. and/13-14
16. ((cervical or cervix) adj (cancer$ or carcinoma$ or neopla$ or dysplas$ or tumor$ or tumour$)).mp.
17. or/12,15-16
18. 8 and 17
19. limit 18 to yr="2002 - 2008"

#### Kidney cancer

1. exp emission tomography/
2. positron$.mp.
3. pet.mp.
4. emission compute$ tomography.mp.
5. Fluorodeoxyglucose F18/
6. fdg.mp.
7. fluorodeoxyglucose.mp.
8. or/1-7
9. exp Kidney Tumor/
10. ((kidney or renal) adj3 (cancer$ or neopla$ or tumor$ or tumour$ or carcino$)).mp.
11. clear cell$.mp.
12. or/9-11
13. 8 and 12
14. limit 13 to yr="2002 - 2008"

#### Ovarian cancer

1. exp Tomography, Emission-Computed/
2. positron$.mp.
3. pet.mp.
4. emission compute$ tomography.mp.
5. Fluorodeoxyglucose F18/
6. fdg.mp.
7. fluorodeoxyglucose.mp.
8. or/1-7
9. exp Ovarian Neoplasms/
10. (ovar$ adj3 (cancer$ or neopla$ or tumor$ or tumour$ or carcino$)).mp.
11. 9 or 10
12. 8 and 11
13. limit 12 to yr="2002 - 2008"

#### Pancreatic cancer

1. exp Tomography, Emission-Computed/
2. positron$.mp.
3. pet.mp.
4. emission compute$ tomography.mp.
5. Fluorodeoxyglucose F18/
6. fdg.mp.
7. fluorodeoxyglucose.mp.
8. or/1-7
9. exp Pancreatic Neoplasms/
10. (pancrea$ adj3 (cancer$ or neopla$ or tumor$ or tumour$ or carcino$)).mp.
11. 9 or 10
12. 8 and 11
13. limit 12 to yr="2002 - 2008"

#### Prostate cancer

1. exp Tomography, Emission-Computed/
2. positron$.mp.
3. pet.mp.
4. emission compute$ tomography.mp.
5. Fluorodeoxyglucose F18/
6. fdg.mp.
7. fluorodeoxyglucose.mp.
8. or/1-7
9. (prostat$ adj3 (cancer$ or neopla$ or tumor$ or tumour$ or carcino$)).mp.
10. 8 and 9
11. limit 10 to yr="2002 - 2008"

#### Small cell lung cancer

1. exp Tomography, Emission-Computed/
2. positron$.mp.
3. pet.mp.
4. emission compute$ tomography.mp.
5. Fluorodeoxyglucose F18/
6. fdg.mp.
7. fluorodeoxyglucose.mp.
8. or/1-7
9. (small-cell adj4 (cancer$ or neopla$ or tumor$ or tumour$ or carcino$)).mp.
10. 8 and 9
11. limit 10 to yr="2002 - 2008"

#### Testicular cancer

1. exp Tomography, Emission-Computed/
2. positron$.mp.
3. pet.mp.
4. emission compute$ tomography.mp.
5. Fluorodeoxyglucose F18/
6. fdg.mp.
7. fluorodeoxyglucose.mp.
8. or/1-7
9. exp Testicular Neoplasms/
10. (teste$ adj3 (cancer$ or neopla$ or tumor$ or tumour$ or carcino$)).mp.
11. (testi$ adj3 (cancer$ or neopla$ or tumor$ or tumour$ or carcino$)).mp.
12. (seminoma$ or teratoma$).mp.
13. or/9-12
14. 8 and 13
15. limit 14 to yr="2002 - 2008"

### Table A2 EMBASE – Ovid Version

Years/issue searched: 2002 to 2008

Search date: 12 March, 2008

#### Bladder cancer

1. exp emission tomography/
2. positron$.mp.
3. pet.mp.
4. emission compute$ tomography.mp.
5. Fluorodeoxyglucose F 18/
6. fdg.mp.
7. fluorodeoxyglucose.mp.
8. or/1-7
9. exp Bladder Tumor/
10. (bladder adj3 (cancer$ or neopla$ or tumor$ or tumour$ or carcino$)).mp.
11. 9 or 10
12. 8 and 11
13. limit 12 to yr="2002 - 2008"

#### Brain cancer

1. exp emission tomography/
2. positron$.mp.
3. pet.mp.
4. emission compute$ tomography.mp.
5. Fluorodeoxyglucose F 18/
6. fdg.mp.
7. fluorodeoxyglucose.mp.
8. or/1-7
9. exp Brain Tumor/
10. (brain adj3 (cancer$ or neopla$ or tumor$ or tumour$ or carcino$)).mp.
11. (glioblastoma$ or astrocytoma$ or oligodendroglioma$).mp.
12. or/9-11
13. 8 and 12
14. limit 13 to yr="2002 - 2008"

#### Cervical cancer

1. exp emission tomography/
2. positron$.mp.
3. pet.mp.
4. emission compute$ tomography.mp.
5. Fluorodeoxyglucose F 18/
6. fdg.mp.
7. fluorodeoxyglucose.mp.
8. or/1-7
9. exp Uterine Cervix Cancer/
10. 8 and 9
11. limit 10 to yr="2002 - 2008"

#### Kidney cancer

1. exp emission tomography/
2. positron$.mp.
3. pet.mp.
4. emission compute$ tomography.mp.
5. Fluorodeoxyglucose F 18/
6. fdg.mp.
7. fluorodeoxyglucose.mp.
8. or/1-7
9. exp Kidney Tumor/
10. ((kidney or renal) adj3 (cancer$ or neopla$ or tumor$ or tumour$ or carcino$)).mp.
11. clear cell$.mp.
12. or/9-11
13. 8 and 12
14. limit 13 to yr="2002 - 2008"

#### Ovarian cancer

1. exp emission tomography/
2. positron$.mp.
3. pet.mp.
4. emission compute$ tomography.mp.
5. Fluorodeoxyglucose F 18/
6. fdg.mp.
7. fluorodeoxyglucose.mp.
8. or/1-7
9. exp Ovary Cancer/
10. (ovar$ adj3 (cancer$ or neopla$ or tumor$ or tumour$ or carcino$)).mp.
11. 9 or 10
12. 8 and 11
13. limit 12 to yr="2002 - 2008"

#### Pancreatic cancer

1. exp emission tomography/
2. positron$.mp.
3. pet.mp.
4. emission compute$ tomography.mp.
5. Fluorodeoxyglucose F 18/
6. fdg.mp.
7. fluorodeoxyglucose.mp.
8. or/1-7
9. exp Pancreas Cancer/
10. (pancrea$ adj3 (cancer$ or neopla$ or tumor$ or tumour$ or carcino$)).mp.
11. 9 or 10
12. 8 and 11
13. limit 12 to yr="2002 - 2008"

#### Prostate cancer

1. exp emission tomography/
2. positron$.mp.
3. pet.mp.
4. emission compute$ tomography.mp.
5. Fluorodeoxyglucose F 18/
6. fdg.mp.
7. fluorodeoxyglucose.mp.
8. or/1-7
9. exp Prostate Cancer/
10. (prostat$ adj3 (cancer$ or neopla$ or tumor$ or tumour$ or carcino$)).mp.
11. 9 or 10
12. 8 and 11
13. limit 12 to yr="2002 - 2008"

#### Small cell lung cancer

1. exp emission tomography/
2. positron$.mp.
3. pet.mp.
4. emission compute$ tomography.mp.
5. Fluorodeoxyglucose F 18/
6. fdg.mp.
7. fluorodeoxyglucose.mp.
8. or/1-7
9. Lung Small Cell Cancer/
10. (small-cell adj3 (cancer$ or neopla$ or tumor$ or tumour$ or carcino$)).mp.
11. 9 or 10
12. 8 and 11
13. limit 12 to yr="2002 - 2008"

#### Testicular cancer

1. exp emission tomography/
2. positron$.mp.
3. pet.mp.
4. emission compute$ tomography.mp.
5. Fluorodeoxyglucose F 18/
6. fdg.mp.
7. fluorodeoxyglucose.mp.
8. or/1-7
9. exp Testis Tumor/
10. (testi$ adj3 (cancer$ or neopla$ or tumor$ or tumour$ or carcino$)).mp.
11. (teste$ adj3 (cancer$ or neopla$ or tumor$ or tumour$ or carcino$)).mp.
12. (seminoma$ or teratoma$).mp.
13. or/9-12
14. 8 and 13
15. limit 14 to yr="2002 - 2008"

### Table A3 CENTRAL (Cochrane Central Register of Controlled Trials, NHS Economic Evaluation Database) - Wiley

Years/issue searched: 2002 to 2008

Search date: 20 March, 2008

#### Bladder cancer

#1 (positron* or pet or tomography or fdg or fluorodeoxyglucose):ti,ab,kw in Clinical Trials
#2 cancer* or carcino* or neopla* or tumor* or tumour*:ti,ab,kw in Clinical Trials
#3 bladder:ti,ab,kw in Clinical Trials
#4 (#2 AND #3)
#5 (#1 AND #4), from 2002 to 2008

#### Brain cancer

#1 (positron* or pet or tomography or fdg or fluorodeoxyglucose):ti,ab,kw in Clinical Trials
#2 neopla* or cancer* or tumor or tumour* or carcino*:ti,ab,kw in Clinical Trials
#3 brain or intracranial:ti,ab,kw in Clinical Trials
#4 (#2 AND #3)
#5 (#1 AND #4), from 2002 to 2008

#### Cervical cancer

#1 (positron* or pet or tomography or fdg or fluorodeoxyglucose):ti,ab,kw in Clinical Trials
#2 cancer* or carcino* or neopla* or tumor* or tumour* or dysplasia:ti,ab,kw in Clinical Trials
#3 cervi*:ti,ab,kw in Clinical Trials
#4 (#2 AND #3)
#5 (#1 AND #4), from 2002 to 2008

#### Kidney cancer

#1 (positron* or pet or tomography or fdg or fluorodeoxyglucose):ti,ab,kw in Clinical Trials
#2 cancer* or carcino* or neopla* or tumor* or tumour*:ti,ab,kw in Clinical Trials
#3 kidney or renal in Clinical Trials
#4 (#2 AND #3)
#5 (#1 AND #4), from 2002 to 2008

#### Ovarian cancer

#1 (positron* or pet or tomography or fdg or fluorodeoxyglucose):ti,ab,kw in Clinical Trials
#2 cancer* or carcino* or tumor* or tumour* or neopla*:ti,ab,kw in Clinical Trials
#3 ovar*:ti,ab,kw in Clinical Trials
#4 (#2 AND #3)
#5 (#1 AND #4)

#### Pancreatic cancer

#1 (positron* or pet or fdg or fluorodeoxyglucose or tomography):ti,ab,kw in Clinical Trials
#2 pancrea*:ti,ab,kw in Clinical Trials
#3 cancer* or neopl* or tumor* or tumour* or carcino* in Clinical Trials
#4 (#2 AND #3)
#5 (#1 AND #4), from 2002 to 2008

#### Prostate cancer

#1 (positron* or pet or tomography or fdg or fluorodeoxyglucose):ti,ab,kw in Clinical Trials
#2 cancer* or carcino* or tumor* or tumour* or neopla*:ti,ab,kw in Clinical Trials
#3 prostat*:ti,ab,kw in Clinical Trials
#4 (#2 AND #3)
#5 (#1 AND #4), from 2002 to 2008

#### Small cell lung cancer

#1 (positron* or pet or tomography or fdg or fluorodeoxyglucose):ti,ab,kw in Clinical Trials
#2 (small cell lung cancer):ti,ab,kw in Clinical Trials
#3 small cell:ti,ab,kw in Clinical Trials
#4 cancer* or neopla* or tumor* or tumour* or carcino* in Clinical Trials
#5 (#3 AND #4)
#6 (#2 OR #5)
#7 (#1 AND #6), from 2002 to 2008

#### Testicular cancer

#1 (positron* or pet or tomography or fdg or fluorodeoxyglucose):ti,ab,kw in Clinical Trials
#2 cancer* or carcino* or tumor* or tomour* or neopla*:ti,ab,kw in Clinical Trials
#3 testi* or teste*:ti,ab,kw in Clinical Trials
#4 (#2 AND #3)
#5 (#1 AND #4), from 2002 to 2008

### Table A4 Scopus

Years/issue searched: 2002 to 2008

Search date: 19 March, 2008

#### Bladder cancer

((TITLE-ABS-KEY(bladder) AND TITLE-ABS-KEY(cancer OR carino* OR neopla* OR tumor OR tumour))) AND (TITLE-ABS-KEY(pet OR positron OR fdg OR fluorodeoxyglucose OR emission comput* tomography) AND DOCTYPE(ar OR re OR cp OR cr) AND PUBYEAR AFT 2001)

#### Brain cancer

((TITLE-ABS-KEY(brain OR intercranial) AND TITLE-ABS-KEY(cancer OR carino* OR neopla* OR tumor OR tumour))) AND (TITLE-ABS-KEY(pet OR positron OR fdg OR fluorodeoxyglucose OR emission comput* tomography) AND DOCTYPE(ar OR re OR cp OR cr) AND PUBYEAR AFT 2001)

#### Cervical cancer

((TITLE-ABS-KEY(cervical OR cervix) AND TITLE-ABS-KEY(cancer OR carino* OR neopla* OR tumor OR tumour))) AND (TITLE-ABS-KEY(pet OR positron OR fdg OR fluorodeoxyglucose OR emission comput* tomography) AND DOCTYPE(ar OR re OR cp OR cr) AND PUBYEAR AFT 2001)

#### Kidney cancer

((TITLE-ABS-KEY(kidney OR renal) AND TITLE-ABS-KEY(cancer OR carino* OR neopla* OR tumor OR tumour))) AND (TITLE-ABS-KEY(pet OR positron OR fdg OR fluorodeoxyglucose OR emission comput* tomography) AND DOCTYPE(ar OR re OR cp OR cr) AND PUBYEAR AFT 2001)

#### Ovarian cancer

((TITLE-ABS-KEY(ovar*) AND TITLE-ABS-KEY(cancer OR carino* OR neopla* OR tumor OR tumour))) AND (TITLE-ABS-KEY(pet OR positron OR fdg OR fluorodeoxyglucose OR emission comput* tomography) AND DOCTYPE(ar OR re OR cp OR cr) AND PUBYEAR AFT 2001)

#### Pancreatic cancer

((TITLE-ABS-KEY(pancrea*) AND TITLE-ABS-KEY(cancer OR carino* OR neopla* OR tumor OR tumour))) AND (TITLE-ABS-KEY(pet OR positron OR fdg OR fluorodeoxyglucose OR emission comput* tomography) AND DOCTYPE(ar OR re OR cp OR cr) AND PUBYEAR AFT 2001)

#### Prostate cancer

((TITLE-ABS-KEY(prostat*) AND TITLE-ABS-KEY(cancer OR carino* OR neopla* OR tumor OR tumour))) AND (TITLE-ABS-KEY(pet OR positron OR fdg OR fluorodeoxyglucose OR emission comput* tomography) AND DOCTYPE(ar OR re OR cp OR cr) AND PUBYEAR AFT 2001)

#### Small cell lung cancer

((TITLE-ABS-KEY(small cell) AND NOT (non) AND TITLE-ABS-KEY(cancer OR carino* OR neopla* OR tumor OR tumour))) AND (TITLE-ABS-KEY(pet OR positron OR fdg OR fluorodeoxyglucose OR emission comput* tomography) AND DOCTYPE(ar OR re OR cp OR cr) AND PUBYEAR AFT 2001)

#### Testicular cancer

((TITLE-ABS-KEY(testic* OR testi* OR teste*) AND TITLE-ABS-KEY(cancer OR carino* OR neopla* OR tumor OR tumour))) AND (TITLE-ABS-KEY(pet OR positron OR fdg OR fluorodeoxyglucose OR emission comput* tomography) AND DOCTYPE(ar OR re OR cp OR cr) AND PUBYEAR AFT 2001)

#### All

(ALL(nopr) AND ALL(national oncologic pet registry)) AND PUBYEAR AFT 2001

## Grey Literature Searches

### Internet Searches

Internet searches were performed using the Google search engine in the following sites:

Website | Database - Organization | Date of search
www.anzctr.org.au | Australian New Zealand Clinical Trial Register (Australia) | 20 March, 2008
www.bcbsa.com | BlueCross BlueShield Association (U.S. | 20 March, 2008
www.cc.nih.gov | NIH Clinical Center; National Institutes of Health (U.S.) | 20 March, 2008
www.clinicaltrials.gov | National Institutes of Health (U.S) | 12 March, 2008
www.controlled-trials.com | International Standard Randomised Controlled Trial Number Register; Science Navigation Group (U.K.) | 20 March, 2008
www.nice.org.uk | Emergency Care Research Institute (U.K.) | 20 March, 2008
www.who.int/ictrp/en/ | International Clinical Trials Registry Platform; World Health Organization | 20 March, 2008
www.wellcome.ac.uk | Wellcome Trust's Clinical Trial Register; Wellcome Trust (U.K.) | 20 March, 2008

### Conference Proceedings

Scientific Meetings | Years
American Society of Clinical Oncology (ASCO) annual scientific meeting | 2006-2007
American Society for Therapeutic Radiology and Oncology (ASTRO) annual scientific meeting | 2006-2007
European Association of Nuclear Medicine (EANM) annual scientific meeting | 2006-2007
European Congress of Radiology annual scientific meeting | 2006-2007
Society of Nuclear Medicine (SNM) annual scientific meeting | 2006-2007