# Abbreviations

Abbreviation: Description
^18^FDG: 18F-fluorodeoxyglucose
AC: carbon-11 acetate
AD: adenocarcinoma
AFP: alpha-fetoprotein
AHRQ: Agency for Healthcare Research and Quality
ASC: adenosquamous carcinoma
ß-HCG: beta-human chorionic gonadotropin
BCG: Bacillus Clamette-Geurin
BEP: bleomycin, etoposide, and platinum
BMI: body mass index
BPH: benign prostatic hyperplasia
CA-125: cancer antigen 125
CCRT: concurrent chemotherapy and radiotherapy
CEA: carcinoembryonic antigen
CHEC: Consensus on Health Economic Criteria
CI: confidence interval
CIN: cervical intraepithelial neoplasia
CMS: Centers for Medicaid and Medicare Services
CNS: central nervous system
COI: conflict of interest
CP: chronic pancreatitis
CS: clinical stage
CT: computed tomography
D: days
DM: diabetes mellitus
DRE: digital rectal examination
EBRT: electron beam radiation therapy
ECOG: Eastern Cooperative Oncology Group
ED: extensive-disease
ERCP: endoscopic retrograde cholangiopancreatography
EPC: Evidence-based Practice Centers
EUS: endoscopic ultrasound
F-FMISO: 18F-fluoromisonidazole
FIGO: Federation Internationale de Gynecologie et d'Obstetrique
FNA: fine needle aspiration
FOV: field of view
GBM: glioblastoma multiforme
GCT: germ cell tumors
GLUT: glucose transport proteins
GnRH: gonadotropin-releasing hormone
H: hours
HPV: human papilloma virus
HR: hazard ratio
ILN: Inguinal lymph node
IPMN: intraductal papillary mucinous neoplasms
IQR: interquartile range
IV: intravenous
LD: limited-disease
LDH: lactate dehydrogenase
LD: lymph nodes
LR: likelihood ratio
MAX: maximum
MET: carbon-11 methionine
M-H: Mantel-Hantzel
MIN: minutes
MLN: mediastinal lymph node
MRCP: magnetic resonance cholangiopancreatography
MO: months
MRI: magnetic resonance imaging
MRS: magnetic resonance spectroscopy
NA: not applicable
ND: not described
NLR: negative likelihood ratio
OSEM: ordered subset expectation maximization
PALN: para-aortic lymph node
PCI: prophylactic cranial irradiation
PET: positron emission tomography
PLN: pelvic lymph node
PLR: positive likelihood ratio
PO: oral
PSA: prostate-specific antigen
PTC: percutaneous transhepatic cholangiography
QUADAS: Quality Assessment of Studies of Diagnostic Accuracy
RCC: renal cell carcinoma
RCT: randomized controlled trial
RH-PLND: radical hysterectomy + pelvic lymphadenectomy
RI: retention index
RMI: risk of malignancy index
ROC: receiver operating characteristic
ROI: region of interest
RT: radiotherapy
SCC-Ag: squamous cell carcinoma antigen
SCLC: small cell lung cancer
SD: standard deviation
SEC: seconds
SIGN: Scottish Intercollegiate Guidelines Network
SLL: second-look laparotomy
SLN: supraclavicular lymph node
SROC: summary receiver operating characteristic
SUV: standardized uptake value
TA: technology assessment
TNMS: tumor, node, metastasis staging
TRUS: transrectal ultrasound
TUR: transurethral resection
TVUS: transvaginal ultrasonography
UICC: Union International Contre le Cancer
US: Ultrasound
VALCSG: Veterans Administration Lung Cancer Study Group
VATAP: Veterans Affairs Technology Assessment Program
WK: weeks
WHO: World Health Organization
YR: years