# PERSONNEL

Amy P. Abernethy, MD, Principal Investigator. Dr. Abernethy, a practicing oncologist and health outcomes researcher, is Assistant Professor of Medicine at Duke University School of Medicine, Assistant Professor of Nursing at Duke University School of Nursing, and Associate Lecturer at Flinders University in South Adelaide, Australia. She is a Senior Fellow of the Duke Center for Clinical Health Policy Research, and a faculty member of the Duke Clinical Research Institute and the Duke Comprehensive Cancer Center Cancer Control Program. Her research has focused on conducting high quality clinical trials that generate evidence-based solutions for common problems in cancer and other chronic life-limiting illnesses, such as pain, dyspnea, and fatigues; a significant portion of her research agenda involves the study of health service delivery models. Dr. Abernethy is PI of an AHRQ-funded technology assessment (TA) of targeted cancer drugs, and has served as a lead investigator on TAs of oral cancer drugs, use of compendia for off-label listing of pharmaceutical products, and psychological interventions for cancer pain. She has held responsibility for all aspects of this project, including study design, convening of the Advisory Panel, the literature search, the Public Forum, key informant teleconferences, synthesis of data, and preparation of the report.

Meenal Patwardhan, MD, MHSA, Co-Investigator. Dr. Patwardhan is a health services researcher and adjunct member of the Duke Center of Clinical Health Policy Research, as well as an Adjunct Assistant Professor of Medicine in Duke University School of Medicine. She has recently moved to a new role at Abbott Laboratories; this transition took place in the middle of this project and she did not have any input into the research or its interpretation after moving to industry. Her work ranges from evidence compilation to implementing best evidence in practice. She has served as the PI of a chronic kidney disease guideline implementation project that involved interviewing several physicians and patients. Dr. Patwardhan has also been the PI of the AHRQ-funded evidence report on Cancer Care Quality Measures: Diagnosis and Treatment of Colorectal Cancer, and has served as a co-investigator for use of compendia for off-label listing (the methodology of which was similar to the current proposal). She participated integrally in design of the study, convening of the Advisory Panel, the Public Forum, preparation for key informant teleconferences.

David B. Matchar, MD, FACP, Co-Investigator and Task Order Director. Dr. Matchar is Director of the Duke Center for Clinical Health Policy Research and Professor of Medicine at Duke University School of Medicine. In addition to clinical expertise, Dr. Matchar will provide methodological expertise in evidence-based medicine, decision analysis, and guideline development. Dr. Matchar has worked with the project team as they interfaced with AHRQ, CMS, and the Advisory Panel, conducted key informant teleconferences, and synthesized and interpreted the data.

Nancy M. Allen LaPointe, PharmD, Co-Investigator. Dr. Allen LaPointe is an Associate Professor of Medicine at Duke University Medical Center and Clinical Associate Professor in Pharmacy at University of North Carolina-Chapel Hill. After ten years of clinical practice and teaching as a Cardiovascular Clinical Pharmacist at Duke University Medical Center, Dr. Allen LaPointe moved to the Duke Clinical Research Institute (DCRI) as the Project Manager for the Duke Center for Education and Research on Therapeutics (CERTs) program, in which she developed and managed all clinical research projects for the research center. From 2002–2007, she was the Program Director for the Duke CERTs. During her eight years at the DCRI, Dr. Allen LaPointe has worked as a member of the DCRI faculty in developing both government and non-government funded clinical research projects and as part of the DCRI clinical operations leadership. Dr. Allen LaPointe’s research has focused on evaluating and improving the use of evidence-based therapies in clinical practice, medication safety and adherence, and risk communication and management. She participated in leading key informant teleconferences, and interpreting the data.

Jane L. Wheeler, MS, Writer. Ms. Wheeler has played a central role in gathering the evidence, and compiling and presenting study results, with responsibility for summarizing key informant input solicited during conference calls, intercalating results, and writing, compiling, and editing the final evidence report. Ms. Wheeler has extensive experience in these tasks; she has been involved in a similar capacity on several concurrent studies including the AHRQ-sponsored evidence report, "Targeted Therapies for Cancer."

R. Julian Irvine, MS, Project Coordinator. Mr. Irvine held responsibility for supervising day-to-day operations, scheduling, setting meeting agendas, organizing results of the literature search, creating and maintaining the database, coordinating the Public Forum, and facilitating communication between the investigators and Public Forum participants, key informants, Advisory Panel members, and officers at AHRQ and CMS. Mr. Irvine is currently project coordinator for several other EPC projects.