# DISCUSSION

This project was designed to describe the impact of payment policy on participant enrollment and retention in clinical trials. It utilized four primary strategies to elucidate this potential problem for which data are largely non-existent. A literature search was conducted to cull from the published medical literature any relevant articles and information that might inform the study. An Advisory Panel, comprised of national experts, was convened to provide guidance to the inquiry as well as to point out specific articles and studies for inclusion. A Public Forum was held on the CMS campus in Baltimore, MD, to solicit public input. A series of teleconference with key informants was held to gather the observations and perceptions of individuals with relevant experiences related to clinical trial recruitment and enrollment, payment policy for costs associated with clinical trials, and the impact of payment policies on patients’ decisions to participate or not participate in clinical trials. And, a draft version of the summary White Paper was presented for public review and comment, with appropriate resulting modifications presented in the final White Paper.

A discussion section under each of the four Strategies (Advisory Panel, Literature Search, Public Forum, Key Informant Teleconferences) comprising this project addresses the key findings from each respective Strategy. Listed below are the main points that have emerged through conduct of this study as a whole.

1. Payment policy does impact clinical trial participation, but data on the extent and magnitude of this influence are difficult to find. There are, however, a few examples of high-profile, high-budget, clinical trials which have encountered problems with enrollment or retention due to payment policies. The impact of payment policies on participation in less visible clinical trials is unclear, as information regarding termination of clinical trials, or delays in their completion, is generally not published. No mechanism exists for collecting data on reasons why patients choose not to participate in clinical trials.
2. The impact of payment policy on clinical trial participation is not uniform across study types, study phases, disease areas, and clinical populations. There is more evidence of this impact on clinical trials studying medical devices than on those investigating new drug treatments, partly reflecting the earlier timing of the FDA policy on IDE exemption and the implications for third-party payment for exempted Category B devices. Studies of the comparative effectiveness of existing therapies, especially in head-on trials, have had particular difficulty when one or both therapy(ies) has been available and reimbursable off-trial. Studies of off-label indications, which are not typically reimbursable outside of the clinical trial setting (except for off-label anticancer therapies), are also especially susceptible to the influence of payment policy. Studies seeking to enroll adults face different challenges than do those enrolling children, with decisions to participate in adult studies being more influenced by payment policy than studies involving children. Finally, studies of interventions for which there is policy of no reimbursement (e.g., obesity interventions) face particular challenges because, since treatment both on and off trial is out-of-pocket, patients have no incentive to enroll in a randomized trial where they might receive placebo.
3. Lack of clarity surrounding responsibility for specific expenses exacerbates the impact of payment policy on clinical trial participation. There is no consensus on which party should pay for which costs when a patient is enrolled in a clinical trial. While “standard of care” costs are commonly assigned to the third-party payer, the definitions of standard of care versus research-related costs remain unclear. This lack of clarity complicates the task of assigning costs to a sponsor or third-party payer, and resulting uncertainty about cost implications may inhibit patients from participating in a study or providers from referring a patient to a study. There is a trend among sponsors and sites to clarify, in advance of opening a study, the locus of responsibility for specific patient care and research-related costs.
4. To circumvent the impedance of payment policy on accrual and retention, investigators are implementing creative solutions to enable them to enroll enough patients to complete their clinical trials. Examples of such strategies include paying for participants’ travel and lodging while on a trial, and appealing to insurance carriers on a case-by-case basis. These sorts of strategies are personnel intensive and/or budgetarily burdensome, make conduct of the trial more cumbersome, and add an unnecessary layer of inefficiency to the research enterprise.
5. Payment policy can impact the evidence base in several ways. When enrollment proceeds slowly because payment policies reduce patients’ willingness to participate in clinical trials, or diminish providers’ interest in directing patients toward clinical trials, the pace of evidence generation slows correspondingly. The evidence base fails to grow in areas where research-derived answers are needed to guide clinical care. When payment policy makes a clinical trial economically infeasible, that trial may be terminated early or never initiated. In either case, evidence fails to be generated in that area. When payment policy steers patients toward registries rather than clinical trials, the quality of evidence may suffer as the preponderance of research results will come from uncontrolled observational studies rather than from rigorously designed RCTs. When payment policy initiates coverage for a device or drug before proof of efficacy has been established, the “cart is put before the horse.” It becomes challenging or impossible to recruit patients to trials of those interventions, and thus very difficult to arrive at a definitive determination of efficacy.
6. Payment policy, through its impact on clinical trials participation, has an impact on disparities in and access to care. Different subsets of the general population – minorities, the uninsured, those with adequate insurance, children, the elderly – are likely to have differing insurance scenarios. Payment policies related to clinical trial participation will therefore affect these groups differently, resulting in different rates of accrual in different subpopulations. If clinical trials cannot enroll representative samples large enough to allow power to detect statistically significant differences in outcomes, the evidence they generate may not be robust, generalizable, or applicable to the relevant population.
7. Payment policies, or policies that are related to payment and clinical trial participation, are developed by various entities including the NIH, CMS, FDA, state legislatures, and third-party payers. Cutting-edge science and meritorious clinical trials are developed through NIH, industry, academia, and others. All of these entities have an interest in the successful conduct of clinical trials, the development of a robust evidence base, and the quality of scientific research and resulting data. Their policies related to reimbursement and financial aspects of clinical trials impact participants and studies in sometimes deleterious ways. Moreover, these policies are not always clear or transparent across agencies and between agencies, industry/sponsors, providers, and the public. Improved communication and coordination among these agencies and organizations would help facilitate the conduct of research, ensure that vital evidence is generated, and thereby uphold the safety and quality of medical care. For example, Medicare Advantage (MA) plans currently do not have access to clinical trial participation information involving MA enrollees, particularly with respect to providers and patients involved in Investigational Device Exemptions; this information resides with CMS, and lack of accessibility may negatively impact MA plans’ ability to effectively manage clinical trial activities and participants. Alignment of payer (including MA plan) policies and local/national coverage determinations is necessary to ensure both access to care and appropriate assignment of costs.
8. Competition between registries and clinical trials appears to be a major concern in the research community. By participating in a registry, a patient can satisfy CED requirements, receive the same coverage as he/she would in the context of a randomized clinical trial, and be assured that the intervention received is the actual treatment. On a clinical trial, by contrast, the individual runs the risk of being randomized to a non-treatment (e.g., placebo) arm. Policy allowing registry participation to substitute for clinical trial participation creates head-on competition for participants, and is likely to slow or impede the development of an evidence base built on data from high-quality randomized controlled trials (RCTs). Instead, the research environment could benefit from a coordinated program of research that articulates a role for both registries and RCTs; such a program would capture the results from both experimental and observational studies, thus building a more completely understanding of the impact of interventions against the backdrop of the disease’s natural history.
9. Blinding, as well as randomization, is threatened by current changes and practices in payment policy. Unblinding in order to facilitate reimbursement by third-party payers was noted as a problem for clinical trials, one that jeopardizes the quality of research results.

## Suggested future directions

Given this backdrop – common agreement that payment policy impacts clinical trials participation, clarity that new approaches are needed to ameliorate these problems, but little data to quantify or describe the phenomenon – there are several areas of action that CMS might consider. Of paramount importance is greater coordination between CMS, the FDA, and the NIH around the common mission of improving the quality of clinical trials and the resulting evidence base, while honoring these agencies’ distinct purposes and roles. It is critical to determine, first, whether a payment policy is in fact interfering with the conduct of clinical trials, and secondly to describe that impact in terms of locus and extent.

A mechanism to collect information on impact, including differential impact by variables such as socioeconomic status and age, will need to be implemented. An efficient vehicle for such a mechanism already exists in ClinicalTrials.gov; here, trials could be required to provide information on their plans for managing reimbursement-related issues, as part of the standard registry process; initial effort would need to be devoted to development of standard definitions, to ensure consistency of reporting and to minimize burden on trial sponsors or investigators. Ideally, this mechanism – collecting information on reimbursement-related plans in advance of studies and information on impact domains during/after conduct of studies – would be created as part of an “intelligent system,” in that data could be regularly queried to identify potential problems and report on them. These reports should be delivered to CMS, FDA, and NIH for joint development of appropriate solutions; data-sharing arrangements should be fully transparent to allow for stakeholder input and to ensure that data-driven policy decisions are fully informed. The system should also store data to enable monitoring of payment policy-related issues in clinical trial participation over time; this system will enable tracking of progress to overcome the identified problems, and will allow payers to manage and plan for costs associated with their enrollees’ participation in clinical trials.

It is important to note that payment policy, though perhaps a significant influence on patients’ decisions to participate in clinical trials, is not the only factor operative in these decisions. Any further inquiry would benefit from complementary exploration of other barriers to enrollment including patients’ perceptions of research, socioeconomic and educational factors, cultural factors, access, provider behavior, physician incentives, and health care performance metrics.

Tension between registries and clinical trials, and the discrepancies between evidence requirements for drugs versus devices, should be addressed in the context of an integrated, carefully constructed, plan for research that incorporates both observational and experimental studies, pursues a goal of obtaining the highest level evidence within practical constraints, acknowledges a valid place for different types of study (RCT, observational/registry) to address different types of research question, and generates a solid long-term understanding of toxicity and impact. Registry requirements, including definition of data to be collected and data-related methodology, will need to be articulated with sufficient oversight to ensure sound quality of data residing in registries. Requirements of clinical trials, legitimately based upon the need for research evidence, should not impair access to innovative technology; rather, policy should be designed so as to facilitate both access to therapies and research in a coherent manner that is safe, respects privacy, and contributes to the care of future generations. Because device trials encounter the preponderance of recruitment difficulties due to payment policy, a coordinated strategy to facilitate conduct of these studies is warranted.

There are several additional actions that CMS could take to minimize the impact of payment policies on clinical trials. At present, the shifting definition of standard of care (SOC) for any given condition allows for interested parties to define SOC to their own advantage; sponsors and health systems disagree on what cost items constitute SOC, and on which costs should be the responsibility of either party. Clearer methods should be developed for assignment of SOC costs, beginning with articulation of what SOC encompasses for the condition at hand. One approach might be to pilot a process of co-sharing SOC costs, report on results of that pilot, and iteratively improve the process based on results. Additionally, to protect the research community’s ability to generate evidence through appropriately designed trials – RCTs as well as observational studies – it is imperative that the financial incentives to participate in a registry rather than a randomized trial (when they exist) do not place RCTs in competition with registries for participants. Instead, a rational approach should be developed to ensure that evidence is generated through studies designed as appropriate to answer the research question at hand. Finally, background structures need to be created to facilitate blinding throughout the duration of a study, perhaps by use of pooled funds that can be accessed, to even out costs in two study arms with differently costed treatments, until the study is complete.

Limitations. The first limitation of this strategy lay in recruitment of key informants. It was initially challenging to identify individuals with relevant background and experiences who might be willing to participate. Upon identifying and contacting potential key informants, we frequently met with reluctance and/or refusal to participate. Principal investigators and clinicians, in particular, were well-buffered by their assistants; a strategy of having one of the study investigators (a physician) contact the potential key informant proved more successful.

A second limitation was met in the group teleconference, as described above. Because of reluctance of the participants to fully participate, the teleconference format was changed to one in which each teleconference included only one key informant. After this change was instituted, individuals who agreed to participate were more open to discussion.

Perhaps the principal limitation of this strategy was noted by key informants themselves. While individuals mentioned that they would like to be able to provide more solid evidence, they spoke from personal experience and mostly provided anecdotes and observations rather than data. Many provided encouragement in the face of what they saw as a difficult task, given the lack of data on this topic and the absence of any clear way to go about gathering information on this topic.