# Background

Evidence-based medicine, classically defined as “the conscientious, explicit and judicious use of current best evidence in making decisions about the care of individual patients,”1 depends fundamentally upon the existence of a rigorous scientific base of research evidence. Since the 1990s, evidence-based medicine has gained widespread acceptance as the best current approach to ensuring optimal patient care and outcomes.2 The cornerstone of an evidence-based approach to patient care is the incorporation of findings from well-designed, well-executed, clinical trials into clinical practice. Research methodology has steadily improved in its sophistication, and clinical trial designs now involve double-blind methods, placebo control, randomization, validated assessment instruments, and large sample sizes to ensure the quality of resulting evidence. Patients benefit directly from the conduct of clinical trials; by participating, they gain access to potential improved outcomes and receive the best available care in the form of individual guidance and expert medical attention from the clinical research team.3 Ultimately, society benefits through the advancement of medical science and corresponding improvement in medical care. Clinicians and institutions benefit from clinical trials; the evidence generated enables them to elevate the quality of care, improve multiple health outcomes, extend survival, and advance educational and research objectives.4 Third-party payers, including federal, state, and private insurers, benefit from clinical trials in that rigorous trials provide solid evidence upon which they can base policy decisions, thereby ensuring that coverage is extended to those interventions proven to enhance outcomes. Clinical research of all types contribute meaningful evidence for decision-making, including observational studies such as registries, non-randomized controlled trials, and more formal randomized controlled studies. This report will focus on more formally controlled trials, since these studies are often difficult to conduct for many reasons, and this may be exaggerated by issues concerning third-party payment policies.

## Current Patterns of Enrollment in Clinical Trials

High-quality clinical trials require sufficient sample size to afford statistical power to detect differences between intervention and control arms. Furthermore, clinical utility of evidence hinges on its generalizability, that is, the validity with which it can be applied to a larger population outside of the study cohort. Thus, a sufficient number of patients willing to participate in clinical trials is necessary not only to enable the conduct of those trials, but also to ensure that results from trials can be generalized to clinical populations of interest. Ideally, the composition of the clinical trial participant population should be representative of the population to which the study results pertain.

At present, clinical trial participation rates are dismal. A recent analysis found that only 2.3 million individuals – less than 1% of the US population – enroll in the approximately 80,000 clinical trials conducted each year.5 Less than 5% of the 1.3 million patients diagnosed with cancer each year take part in clinical trials6,7; rates of participation are disproportionately low among elderly patients.8,9 While 61% of all cancer cases occur among the elderly (age >65 years), this age group accounts for only 32% of participants in phase II and III clinical trials. Although the average age of all cancer patients is 63 and of new cancer patients is 61, the average age of cancer clinical trials participants is 32.^8,9^ A recent meta-analysis examined the characteristics of the >40,000 patients who participated in 141 trials included in cardiovascular disease technology assessments that CMS uses to inform coverage decisions; the meta-analysis found that study populations differed significantly from the Medicare beneficiary population, with participants more likely to be male, younger, and non-US residents.10

Low and sociodemographically uneven participation rates in clinical trials reduce the capacity of investigators to build a robust evidence base. The advancement of evidence-based medicine is impeded when lack of participants leads to the closure or failure of important studies, prolongs research schedules, and slows the translation of new therapies into clinical practice.11–13 When study populations are not representative of the relevant clinical population, the validity and utility of the resulting evidence is suspect. Millions of public dollars are lost when scientifically-important National Institutes of Health (NIH)-funded clinical trials cannot be completed due to inadequate recruitment. It is therefore critical to identify, clarify, and address issues that lead to patients’ nonparticipation, limited participation, or termination of participation in clinical trials.

## Factors Influencing Patient Recruitment and Retention

Many factors are likely to be at play during the recruitment process. From the clinical side, limiting factors may include physician bias or awareness, trial availability, and selection processes. In one American Society of Clinical Oncology (ASCO)-sponsored survey, for example, 3,550 oncologist-respondents stated that they considered 20% of their patients appropriate for trial participation. However, due to limited time, staff, and resources, the physicians approached only 10% of their patients, and only 5% were actually enrolled.14 Among patients who are approached to enroll in a trial, some may be excluded simply because the protocol is not available in their area, some may fail to meet eligibility requirements, while others may mistrust the medical system or simply be unwilling to participate.15,16

Although 70% of U.S. adults indicate that they would be somewhat or highly willing to participate in a study7, the reality of participation behavior is quite different. According to a landmark study of nearly 6,000 cancer patients, of the 15–20% of patients who were aware of trial availability, approximately 75% chose not to participate. Patient respondents indicated various reasons for declining to enroll: 37% felt the standard treatment to be better; 31% feared receiving placebo; 22% feared being treated as a “guinea pig”; 21% cited travel requirements; and 20% declined due to uncertainty about insurance coverage.17 Other studies have cited as barriers the following patient perceptions: treatment might be too severe or too toxic; the trial might involve additional testing and discomfort; the primary-care physician might know less about the study treatment than about standard care; and trial requirements might be too inconvenient.7 Although such fears are generally inconsistent with the experiences of patients who actually participate in trials, these misperceptions nevertheless significantly affect rates of enrollment.17

In addition to factors that influence participation among patients of all ages, there are special considerations that may affect recruitment of the older adult into clinical trials: eligibility requirements including protocol age limits, comorbidities, or previous disease history; concomitant medications; lack of awareness of advancements in reduction of treatment toxicity; perceptions of reduced potential benefit and reduced tolerability; possibility of functional impairments; and lack of financial, logistical, and social support.17,18

## Third-party Payment Policies

Third-party payment policies may be significant among factors that influence patients’ willingness to participate in clinical trials. Guidance from the Office for Human Research Protections requires researchers to inform subjects of the alternatives available to participating in the trial, and this would include making subjects aware of the availability of third-party reimbursement for treatment outside the research setting. Various plausible scenarios are supported by anecdotal evidence, though data do not exist to describe and quantify the actual impact of payment policy on clinical trial participation. First, when third-party payers reimburse for a diagnostic or therapeutic treatment outside of a trial setting, patients may be less likely to participate in trials studying that intervention. They do not need to be enrolled in a trial in order to gain access to the intervention, and by not participating in a trial, they avoid the risk of being randomized to a control condition rather than to the intervention. Second, when third-party payers initiate coverage for an intervention under study while clinical trials investigating that intervention are still open, enrollment may slow down or even halt. Patients lose the financial incentive to participate, and may make a rational decision to avoid the extra demands entailed in the clinical trial (e.g., completing study questionnaires) by simply accessing the intervention off-trial. Third, when third-party payers decide, after a study has begun, to cover treatment for patients who are not involved in the clinical trial, but not to reimburse patients who are enrolled, patients may become less willing to enroll, or continue, in the trial. Fourth, when two arms of a trial involving two interventions have distinct payment structures for each intervention, patients may take financial factors into account in their decisions regarding participation. And fifth, third-party payment structures may contribute or may be perceived to contribute additional financial and time burdens to people who participate in trials (e.g., additional paperwork, timing of reimbursements).

Overall, the lack of national consensus regarding financial responsibility for clinical trial-related healthcare costs has resulted in uneven reimbursement policies. This lack of clarity has contributed to a general environment of uncertainty about third-party coverage, which may itself hamper recruitment efforts.19 Because payment policies carry the potential for widespread and long-term repercussions, their possible impact on clinical trial participation and thereby on the evidence base warrants serious consideration. Ultimately, if they weaken the research structure and lower the quality of evidence, they will undermine informed policy decision making.

## Current/Evolving Legislative Climate

Because CMS plays a major role in the public policy arena, its position with regard to negotiating the tension between support of beneficiaries’ access to emergent medical interventions and maintenance of high standards for evidence-based coverage is subject to particular scrutiny.20 CMS has implemented several initiatives that attempt to promote evidence-based clinical and reimbursement practices, as well as respond to the evolving landscape of evidence-based medicine.21

Clinical Trials Policy National Coverage Decision (NCD). A Presidential Executive Memorandum was the impetus for allowing Medicare to pay for routine health care costs incurred by Medicare beneficiaries participating in clinical trials and resulted in CMS’s 2000 National Coverage Determination.22 Intended specifically to encourage the participation of senior citizens in clinical trials, the NCD implemented coverage for “routine” costs – broadly interpreted as those costs normally covered by Medicare outside the context of a clinical trial. The reconsideration of the policy finalized in October 2007 expanded the definition of such costs to include additional beneficiary items and services that had not previously been covered. While expanding coverage in 2007, the implementation of this policy has been challenging and questions concerning its legal authority persist.

Coverage with Evidence Development (CED). Required by law to provide coverage only for medical interventions deemed “reasonable and necessary,” CMS faces the challenge of promoting innovation without sacrificing scientific rigor or fiscal prudence.23 Therefore, it recently exercised its national coverage authority to help improve access to promising but unproven medical technologies via the Coverage with Evidence Development Guidance Document.18 Intended to be used infrequently, it not only speeds delivery of state-of-the-art therapies to eligible patients, but also facilitates development of the evidence base in order to inform future policy decisions. CED provides coverage for items and services for which there is demonstrable medical benefit, but that do not yet meet Medicare’s requisite standards of evidence of effectiveness in the relevant Medicare population. CED requires, as a condition for coverage, that the intervention be performed within a research context.23,24

Two policy mechanisms – each with its own goals, methods, and statutory authorities – identify specific research circumstances that may qualify for CED. First, Coverage with Appropriateness Determination (CAD) applies when CMS decides that reimbursement for an otherwise eligible medical technology must be linked to the collection of extra clinical data needed to ensure its delivery to appropriate patients according to NCD specifications. Second, Coverage with Study Participation (CSP) enables certain experimental interventions to be deemed reasonable and necessary, and thus eligible for reimbursement, only when delivered in the context of clinical research study that is expected to contribute reliable and valid evidence of benefits and risks, and that furthermore affords additional safety protocols, patient protections, monitoring, and clinical expertise.25 Collection of registry data may fulfill CED clinical research requirements for CSP.

Access to Cancer Clinical Trials Act of 2007. This bill seeks to amend the Public Health Service Act, Employee Retirement Income Security Act of 1974, and Internal Revenue Code of 1986 to require group and individual health insurance coverage and group health plans to cover beneficiaries who are participating in approved cancer clinical trials. Sponsored by Deborah Pryce, it was introduced into the House of Representatives (H.R. 2676) on June 12, 2007. Subsequently, it was re-introduced into the House of Representatives (H.R. 716) by Steve Israel on January 27, 2009 and into the Senate (S. 408) by Sherrod Brown on February 26, 2009. Current status of the bill can be located at http://thomas.loc.gov/cgi-bin/thomas.

The Medicare Improvements for Patients and Providers Act (MIPPA) of 2008. This Act became public law No:110-275 on July 15, 2008. It amends titles XVIII and XIX of the Social Security Act (SSA) to extend expiring provisions under the Medicare Program, to improve beneficiary access to preventive and mental health services, to enhance low-income benefit programs, and to maintain access to care in rural areas, including pharmacy access, and for other purposes. Section 184 in MIPPA amends Section 1833 of the SSA with “(w) Methods of Payment – The Secretary may develop alternative methods of payment for items and services provided under clinical trials and comparative effectiveness studies sponsored or supported by an agency of the Department of Health and Human Services, as determined by the Secretary, to those that would otherwise apply under this section, to the extent such alternative methods are necessary to preserve the scientific validity of such trials or studies, such as in the case where masking the identity of interventions from patients and investigators is necessary to comply with the particular trial or study design.”

Although CMS decisions since 2000 have been most commonly cited as the national reimbursement drivers of evidence development, other policies also influence clinical trials participation, most notably:

Reimbursement under an Investigational Device Exemption (IDE), 1995. A device is any instrument, implement, machine, contrivance, implant, in vitro reagent, or other similar or related article, including a component part, or accessory which is intended for use in the diagnosis of disease or other conditions, or in the cure, mitigation, treatment or prevention of disease in man or other animals, and does not achieve any of its primary intended purposes through chemical action.

Food and Drug Administration (FDA) marketing clearance is usually required for a drug or device to be reimbursed. Prior to 1995, Medicare did not cover any experimental or investigational devices. In 1995, after an Inter-Agency Agreement between the Health Care Financing Administration (HCFA) and FDA, Medicare issued regulations exempting certain devices being investigated in an IDE trial.26–35

The Medicare Prescription Drug, Improvement, and Modernization Act of 2003, Subtitle D, Section 731 required the national coverage determination process to be more transparent for the public, adhere to timelines for considerations, and required payment for coverage of routine costs provided to beneficiaries participating in certain IDE Category A clinical trials.