# Key Informants

CMS | Sidney Trieger, one anonymous participant
FDA | Dr. Wiley Chambers, Dr. Thomas Gross, two anonymous participants
NIH | Dr. David Gordon, Bryan Walker, Dr. John Gallin
Business/Employers/Insurers | Bruce Bradley (General Motors), Gwen Thompson (General Motors), Helen Darling (National Business Group on Health and Institute of Medicine Evidence-based Medicine Roundtable), Dr. Don Bradley (Blue Cross Blue Shield of North Carolina)
Pharmaceutical Industry | Lee Scheible (Eli Lilly), Linda House (Eli Lilly), one anonymous participant
Patient Advocacy Groups | Holly D’Addurno (North Carolina Leukemia and Lymphoma Society), George Dahlman (National Leukemia and Lymphoma Society), Rosemary Rosso (National Breast Cancer Coalition)
Study PI or Coordinator | Dr. Keith Sullivan (SCOT trial PI), Holly Burch (CORAL 1 trial Clinical Research Coordinator, five anonymous participants