# Teleconference Script for Obtaining Oral Consent

Introduction to teleconferences being conducted as one component of “Horizon Scan: To what extent do changes in third-party payment affect clinical trials and the evidence base?”

NOTE: This script was designed for the teleconferences as originally proposed – in small group format. When the teleconference format was changed to include key informants individually rather than in small groups, the script was read in full but the change in format was noted.

[underlined: VERBAL CONSENT]

[Read to teleconference participants as a group, at the outset of each conference call. In the case of a call with only one person, read the script as if there is only one key informant on the call.]

Hello, my name is […] and on the call with me is […; other project personnel say hello.] We are part of a team of investigators at Duke who are gathering input for a white paper that will assist the Center for Medicare and Medicaid Services (CMS) in its decisions regarding payment policy, especially the timing of initiating coverage, for new therapeutic agents. This teleconference today is one of several mechanisms for collecting input from diverse sources with various perspectives on the payment policy issue. Our inquiry and discussion will help to answer key questions related to Medicare coverage policies; specifically:

a. To what extent do changes in third-party payment policies affect the conduct of clinical trials, particularly the accrual and retention of patients to participate in trials?
b. What impact do differing payment structures for interventions under study in clinical trials have on patients’ participation in those trials?
c. Do payment factors have an impact on the quality of subsequently accumulated evidence, and if so, what is the nature of that impact?

To answer these questions, we are convening, in a series of teleconferences, individuals whom we view to be “key informants” – people with on-the-ground experiences related to the topic of payment policy and its impact on clinical trials. Each of you has been specifically selected as a participant in one of these teleconferences since we anticipate that you have a critical understanding of the topic generally, or of some specific element of the topic that is a key aspect to report and/or explore within the final white paper report that will come from this project.

It is important to understand that this is a policy project, where the main output will be a white paper summary. The white paper will be delivered to CMS and the public for the purpose of informing future-decision decision-making on the topic of third-party payment for clinical trials. However, while we call it a policy project, like preparing any report, we must conduct some background research to gather the content. This teleconference is part of that information-gathering process. The topic is compelling, and therefore there is conceivably some minor risk that disclosure of what you say -- and attribution of that input to you -- would put you at risk for personal or civil liability. Hence, we seek your oral consent to participate, after we review the details of the teleconference and the careful processes we are using to protect your confidentiality. There will be no signed documents linking you to the research.

I will first read the salient points:

- This teleconference will last approximately one hour, and will be digitally audiorecorded.
- The content of this teleconference will be used in development of a white paper, but otherwise statements provided by individuals will not become part of the public record.
- A list of key informants, i.e., teleconference participants, will be included with the white paper. At the end of this oral consent process, I will ask you if you agree to have your name included in this list of key informants. You are not required to do so.
- We will maintain confidentiality by attaching no personal identifying information to any content provided, so nothing that you say can be directly linked back to you within our report.
- Digital audiorecordings will be stored on a secure server at Duke and will only be accessible only to the investigators to prepare the report. They will not be shared with CMS or become part of the public record, although they may be made available to members of the Duke IRB in the event of an internal audit. The digital audiofiles will be destroyed 6 years after the project is complete.
- We request that members of the teleconference also maintain confidentiality by not disclosing information gained during the teleconference to others not involved in today’s session, and by not disclosing the identity of any person who provided specific information.
- While we are working hard to maintain confidentiality, there is a small potential risk that specific statements may be traced back to specific informants. This risk is similar to that involved in discussions within any professional setting. We ask that all participants help to minimize this risk by remaining cognizant of the importance of confidentiality and adhering to these terms of privacy and non-disclosure.
- The Duke University Medical Center IRB (IRB reference number Pro00004165) has approved how we are handling these teleconferences.

Now I am going to go through the participants in today’s call one-by-one, and ask each person individually to respond with “I consent” if these terms are agreeable. If you do not agree with these terms, please respond with “I do not consent” and you will be free to exit the teleconference; any key informant has the option to discontinue participation at any point during the conference call. I will also ask you if you are willing to have documentation linking you to this research project, in other words, if you are willing to be included in the list of key informants within our white paper. Please indicate “I agree to be in the listing of key informants” or “I do not wish to be in the listing of key informants.” If you do not want to be in the list, we will count you as an anonymous key informant in the final tally of the number of teleconference participants. Are there any questions?

[If not, proceed as below.]

The statement to which you will respond with “I consent” or “I do not consent” is the following:

“I understand that the teleconference in which I am about to participate will solicit information that will be used to generate a white paper for CMS. I am being asked to describe experiences which I have had with payment policy impact on clinical trials. Any information I provide may be used in development of the white paper, and may conceivably be inadvertently linked to me in the public domain – though careful precautions are in place to ensure confidentiality. I will participate in this call without disclosing my own identity or that of any other participant.”

The statement to which you will respond with “I agree to be in the listing of key informants” or “I do not wish to be in the listing of key informants” is the following:

“Within the final white paper there will be a list of the key informants interviewed. This will be a listing only, and no specific statements, comments, or concerns will be linked with any individual participant. You can elect to not be included in this listing, and we will count you as an anonymous key informant. Please indicate whether you agree to be in this listing.”

[Proceed to call out names individually, in alphabetical order.]