# Articles from the Non-Medical Press Included in Literature Review

ARTICLE TITLE | SOURCE | DATE
Report Claims Clinical Trials Miss Many Populations | Scout News, LLC | April 1, 2008
Participants Left Uninformed in Some Halted Medical Trials | New York Times | October 30, 2007
Duke Studying Impact of Clinical Trial Coverage on Enrollment for CMS | The Gray Sheet | October 1, 2007
Medicare’s Coverage With Evidence Development: A Policy-Making Tool in Evolution | Journal of Oncology Practice | November 2007
Concentric Medical stroke treatment cleared | Silicon Valley/ San Jose Business Journal | August 31, 2007
FDA Weighs Flexibility in Trials of Heart Treatment | New York Times | September 21, 2007
FDA: Panel Recommends Reduced Restrictions on Ablation Trials | New York Times | September 21, 2007
AF Ablation Devices Need Randomized Trials, Advisory Panel Tells FDA | The Gray Sheet | October 1, 2007
Patient Registries’ Impact On Clinical Trials Debated At IoM, CMS Meetings | The Pink Sheet | October 15, 2007
Commercializing Clinical Trials—Risks and Benefits of the CRO Boom | New England Journal of Medicine | October 4, 2007
Reimbursement, Not Off-Label Use, May be Hindering Carotid Stent Trials | The Gray Sheet | October 22, 2007
Cardiac-Resynchronization Therapy in Heart Failure with Narrow QRS Complexes | New England Journal of Medicine | November 6, 2007
Resynchronization Misses Endpoint in St. Jude-Sponsored RethinQ Trial | Health News Daily | November 7, 2007
Multi-MERCI: Higher Recanalization, Lower Mortality With Newer MERCI Retriever | Medscape Medical News | February 15, 2007
Medical Privacy Rule May Hurt Research | Associated Press | November 13, 2007
Renal Stenting Surprise: CMS Proposes To Keep Coverage Status Quo | Health News Daily | November 26, 2007
Clinical Trial Modernization, Outsourcing Concerns Are Focus Of FDA/Duke Effort | The Pink Sheet | December 3, 2007
A Different ‘Right to Life’ | Wall Street Journal | January 11, 2008
Supreme Court Lets Stand Experimental-Drug Ruling | Washington Post | January 15, 2008
CREST Update: Meeting the challenges of a randomized clinical trial | Correspondence from AHRQ | January 15, 2008
Sharing a commitment to improve cardiovascular devices [Part I: Identifying holes in the safety net and Part II: Sealing holes in the safety net] | American Heart Journal | June, 2004
A Review of Prostate Cancer Leaves Men in a Muddle | New York Times | February 26, 2008
Medicare to Revisit Clinical Trial Policy, Consider New Coverage Decision, AHLA Told | Health Care Daily Report | May 9, 2008
High-dose immunosuppressive therapy and autologous hematopoietic cell transplantation for severe systemic sclerosis: long-term follow-up of the US multicenter pilot study | Blood | August 15, 2007
Variation in Approval by Insurance Companies of Coverage for Autologous Bone Marrow Transplantation for Breast Cancer | New England Journal of Medicine | February 17, 1994
Prospective Evaluation of Cancer Clinical Trial Accrual Patterns: Identifying Potential Barriers to Enrollment | Journal of Clinical Oncology | March 15, 2001
Impact of the Year 2000 Medicare Policy Change on Older Patient Enrollment to Cancer Clinical Trials | Journal of Clinical Oncology | January 1, 2006