# Peer-reviewed Articles Abstracted for Literature Review

Aaron H, Gelband H. Medicine Io, editor. Extending Medicare Reimbursement in Clinical Trials. Washington DC. National Academies Press. 2000.
Anonymous. Evaluation of emerging technologies for coronary revascularization. Participants in the National Heart, Lung, and Blood Institute Conference on the Evaluation of Emerging Coronary Revascularization Technologies. Circulation. 1992;85(1):357-361. [pmid: 1728468].
Anonymous. ASCO urges passage of bill to guarantee Medicare coverage of cancer clinical trials. Oncology (Huntington). 1999;13(5):642.
Bagley G, Maxwell R. Linking Medicare Covereage to Research Participation: Resonable and Necessary?. 2005;Vol. 2007.
Berger RL, Celli BR, Meneghetti AL, et al. Limitations of randomized clinical trials for evaluating emerging operations: the case of lung volume reduction surgery.[see comment]. Annals of Thoracic Surgery. 2001;72(2):649-657. [pmid: 11515928].
Britton A, McKee M, Black N, et al. Threats to applicability of randomised trials: exclusions and selective participation. Journal of Health Services & Research Policy. 1999;4(2):112-121.
Carino T, Sheingold S, Tunis S. Using clinical trials as a condition of coverage: lessons from the National Emphysema Treatment Trial. Clinical Trials. 2004;1(1):108-114. discussion 115-21. [pmid: 16281466].
Carino T, Williams RD 2nd, Colbert AM, Bridger P. Medicare's coverage of colorectal cancer drugs: a case study in evidence development and policy. Health Affairs. 2006;25(5):1231-1239. [pmid: 16966718].
Centers for Medicare & Medicaid Services. Proposed Decision Memo for Clinical Trial Policy (CAG-00071R). Vol. 2007: CMS; 2007:Decision Summary of Clinical Trial Policy.
Davis CK. The impact of prospective payment on clinical research. JAMA. 1985;253(5):686-687. [pmid: 3918186].
Dept. of Health and Human Services. Secretary OotP, editor. President Clinton takes new action to encourage participation in clinical trials. Medicare will reimburse for all routine patient care costs for those in clinical trials. White House Press Release. Washington, DC. The White House. 2000;Vol. 2000.
Dunn LB, Gordon NE. Improving informed consent and enhancing recruitment for research by understanding economic behavior.[see comment]. JAMA. 2005;293(5):609-612. [pmid: 15687316].
Excellus Incorporated. (Excellus, Inc.). A Rational Clinical Trial Payment Policy: Lessons from the Use of Bone Marrow Transplantation for Metastatic Breast Cancer. 2002. May.
Fleming ID. Clinical trials for cancer patients. The community practicing physician's perspective. Cancer. 1990;65(10 Suppl):2388-2390. [pmid: 2334879].
Gattis WA, O'Connor CM, Hasselblad V, et al. Usefulness of an elevated troponin-I in predicting clinical events in patients admitted with acute heart failure and acute coronary syndrome (from the RITZ-4 trial). American Journal of Cardiology. 2004;93(11):1436-1437. [pmid: 15165935].
Goldman DP, Berry SH, McCabe MS, et al. Incremental treatment costs in national cancer institute-sponsored clinical trials. JAMA. 2003;289(22):2970-2977. [pmid: 12799405].
Gross CP, Murthy V, Li Y, et al. Cancer trial enrollment after state-mandated reimbursement.[see comment]. Journal of the National Cancer Institute. 2004;96(14):1063-1069. [pmid: 15265967].
Gross CP, Wong N, Dubin JA, et al. Enrollment of older persons in cancer trials after the medicare reimbursement policy change. Archives of Internal Medicine. 2005;165(13):1514-1520. [pmid: 16009867].
Hagberg H, Gisselbrecht C, group Cs. Randomised phase III study of R-ICE versus R-DHAP in relapsed patients with CD20 diffuse large B-cell lymphoma (DLBCL) followed by high-dose therapy and a second randomisation to maintenance treatment with rituximab or not: an update of the CORAL study. Annals of Oncology. Suppl 4. 2006;17:iv31-iv32. [pmid: 16702182].
Hill KP, Ross JS, Egilman DS, et al. The ADVANTAGE Seeding Trial: A review of internal documents. Ann Intern Med. 2008;149:251-258. [pmid: 18711155].
Hillner BE. Barriers to clinical trial enrollment: are state mandates the solution?[comment]. Journal of the National Cancer Institute. 2004;96(14):1048-1049. [pmid: 15265958].
Kelahan AM. Dissemination of information on legislative mandates and consensus-based programs addressing payment of the costs of routine care in clinical trials through the World Wide Web.[see comment]. Cancer. 2004;100(6):1238-1245. [pmid: 15022292].
Lewis JH, Kilgore ML, Goldman DP, et al. Participation of patients 65 years of age or older in cancer clinical trials. Journal of Clinical Oncology. 2003;21(7):1383-1389. [pmid: 12663731].
Martel C, Li Y, Beckett L, et al. Cancer clinical trial (CCT) accrual patterns: a prospective re-evaluation of barriers to enrollment following passage of legislation requiring third-party payer coverage of CCT costs in California [Abstract No. 2112]. 2003 ASCO Annual Meeting: ASCO. 2003.
McCabe MS. Reimbursement of biotherapy: present status, future directions--perspectives of the hospital-based oncology nurse. Seminars in Oncology Nursing. 1992;8(4 Suppl 1):3-7. [pmid: 1462056].
Miller R. Does Coverage of Renal Intervention Hinder Trials? Stakeholders Disagree. Health News Daily. 2007;19(117).
Mitka M. Regulations, payment affect stroke research. JAMA. 2007;297(12):1304-1305. [pmid: 17392230].
Moran M. New Jersey insurers will pay for care in cancer clinical trials. Vol. 2007: American Medical News. 2000.
Morris L. (Chief Counsel to the Inspector General). Re: OIG Advisory Opinion No. 04-01. 2004;Vol. 2007.
Murphy TP. Interventional Radiologists Urged to Recruit More Patients for CORAL Study. Vol. 2007: Radiological Society of North America. 2006.
National Cancer Institute. NCI PDQ database of clinical trials.: National Cancer Institute. 2007.
Pearson SD, Miller FG, Emanuel EJ. Medicare's requirement for research participation as a condition of coverage: is it ethical?[see comment]. JAMA. 2006;296(8):988-991. [pmid: 16926358].
Straube BM. How changes in the Medicare coverage process have facilitated the spread of new technologies. Health Affairs. Suppl Web Exclusives. 2005:W5-314-W5-316.
Thornton D. (Chief Counsel to the Inspector General). Re: National Emphysema Treatment Trial (NETT) Advisory Opinion No. 00-5. 2000;Vol. 2007.
Tunis SR, Pearson SD. Coverage options for promising technologies: Medicare's 'coverage with evidence development'. Health Affairs. 2006;25(5):1218-1230. [pmid: 16966717].
Unger JM, Coltman CA Jr, Crowley JJ, et al. Impact of the year 2000 Medicare policy change on older patient enrollment to cancer clinical trials. Journal of Clinical Oncology. 2006;24(1):141-144. [pmid: 16330670].
US General Accounting Office. (US General Accounting Office). NIH Clinical Trials: Various Factors Affect Patient Population. 1999 September 1999. Report No.: GAO/HEHS-99-182 NIH Clinical Trials.
Vogelzang NJ, Richards JM. Third-party reimbursement issues during a phase I trial of interleukin-2. Journal of the National Cancer Institute. 1989;81(7):544-545. [pmid: 2784171].
Yarbro JW, Mortenson LE. The need for Diagnosis-Related Group 471. Protection for clinical research. JAMA. 1985;253(5):684-685. [pmid: 3918185].