# Glossary of Abbreviations

ACCC: Association of Community Cancer Centers
AMD: Age-related macular degeneration
AREDS2: Age-Related Eye Disease Study 2
ASCO: American Society of Clinical Oncology
CAD: Coverage with Appropriateness Determination
CAS: Carotid artery stenting
CATT: Comparison of AMD Treatment Trials
CEA: Carotid endarterectomy
CED: Coverage with Evidence Development
CMS: Center for Medicare and Medicaid Services
CORAL: Cardiovascular Outcomes in Renal Atherosclerosis Disease
CREST: Carotid Revascularization Endarterectomy vs. Stenting Trial
CRP: Clinical Research Policy
CSP: Coverage with Study Participation
CTP: Clinical Trials Policy
EDICT: Eliminating Disparities in Clinical Trials
FDA: Food and Drug Administration
HCFA: Health Care Financing Administration
HDE: Humanitarian device exemption
HHS: Health and Human Services
HMO: Health maintenance organization
IDE: Investigational device exemption
IRB: Institutional review board
MDMA: Medical Device Manufacturers Association
NCCN: National Comprehensive Cancer Network
NCD: National Coverage Determination
NCI: National Cancer Institute
NIH: National Institutes of Health
NPRM: Notice of Proposed Rule Making
PFO: Patent foramen ovale
PI: Principal Investigator
PMA: Pre-market approval
QOL: Quality of life
RCT: Randomized controlled trial
SCOT: Scleroderma: Cyclophosphamide or Transplantation
TROPICS2: Tenecteplase for Restoration in Dysfunctional Central Venous Access Catheters