# References

1 Sackett DL, Rosenberg WM, Gray JA, et al. Evidence based medicine: what it is and what it isn't.[see comment]. BMJ. 1996;312(7023):71-72. [pmid: 8555924].
2 ASCO. Medicare's coverage with evidence development: A policy-making tool in evolutio. Journal of Oncology Practice. 2007;3(6):296-301. [pmid: 20859385].
3 NCI. Clinical trials: Questions and answers. May. 19. 2006. ed. 2006.
4 NCI. Incorporating cancer clinical trials into your practice. 2008.
5 Weinberg A, Grossberg D. (Chronic Disease Prevention and Control Research Center at Baylor College of Medicine, in collaboration with the Intercultural Cancer Council). Major deficiencies in the design and funding of clinical trials: A report to the nation improving on how human studies are conducted. 2008. April. 1.
6 Coalition of Cancer Cooperative Groups. The clinical trial awareness gap: Coalition study reveals high satisfaction, low participation. Clinical Trial Matters. 2006:1-3.
7 Comis RL, Miller JD, Aldige CR, et al. Public attitudes toward participation in cancer clinical trials.[comment]. Journal of Clinical Oncology. 2003;21(5):830-835. [pmid: 12610181].
8 Hutchins LF, Unger JM, Crowley JJ, et al. Underrepresentation of patients 65 years of age or older in cancer-treatment trials.[see comment]. N Engl J Med. 1999;341(27):2061-2067. [pmid: 10615079].
9 Lewis JH, Kilgore ML, Goldman DP, et al. Participation of patients 65 years of age or older in cancer clinical trials. Journal of Clinical Oncology. 2003;21(7):1383-1389. [pmid: 12663731].
10 Dhruva SS, Redberg RF. Variations between clinical trial participants and Medicare beneficiaries in evidence used for Medicare national coverage decisions.[see comment]. Arch Intern Med. 2008;168(2):136-140. [pmid: 18227358].
11 Ehrlich PF, Newman KD, Haase GM, et al. Lessons learned from a failed multi-institutional randomized controlled study. Journal of Pediatric Surgery. 2002;37(3):431-436. [pmid: 11877662].
12 Haidich AB, Ioannidis JP. Effect of early patient enrollment on the time to completion and publication of randomized controlled trials. American Journal of Epidemiology. 2001;154(9):873-880. [pmid: 11682370].
13 Lara PN Jr, Paterniti DA, Chiechi C, et al. Evaluation of factors affecting awareness of and willingness to participate in cancer clinical trials. Journal of Clinical Oncology. 2005;23(36):9282-9289. [pmid: 16361626].
14 NCI. Doctors, patients face different barriers to clinical trials. 2005.
15 Giuliano AR, Mokuau N, Hughes C, et al. Participation of minorities in cancer research: the influence of structural, cultural, and linguistic factors. Ann Epidemiol. 2000;10(8 Suppl):S22-S34. [pmid: 11189089].
16 Lara PN Jr, Higdon R, Lim N, et al. Prospective evaluation of cancer clinical trial accrual patterns: identifying potential barriers to enrollment. Journal of Clinical Oncology. 2001;19(6):1728-1733. [pmid: 11251003].
17 Comis RL, Aldigé CR, Stovall EL, et al. (Coalition of National Cancer Cooperative Groups, Cancer Research Foundation of America, Cancer Leadership Council, and Oncology Nursing Society). A quantitative survey of public attitudes towards cancer clinical trials. 2000.
18 CMS. National coverage determinations with data collection as a condition of coverage: Coverage with evidence development. 2006;Vol. 2008.
19 Hillner BE. Barriers to clinical trial enrollment: are state mandates the solution?[comment]. Journal of the National Cancer Institute. 2004;96(14):1048-1049. [pmid: 15265958].
20 Tunis SR, Pearson SD. Coverage options for promising technologies: Medicare's 'coverage with evidence development'. Health Aff (Millwood). 2006;25(5):1218-1230. [pmid: 16966717].
21 CMS. Medicare clinical trials policies overview. 2008;Vol. 2008.
22 CMS. Medicare coverage issues manual. Health and Human Services, ed. 2000.
23 Tunis SR. A clinical research strategy to support shared decision making. Health Aff (Millwood). 2005;24(1):180-184. [pmid: 15647229].
24 Phurrough S, Graves P, Fitterman LK. Decision memo for clinical trial policy (CAG-0071R). 2007;Vol. 2008.
25 CMS. Proposed decision memo for clinical trial policy (CAG-0071R2). 2007;Vol. 2008.
26 Health Care Financing Administration. Criteria and Procedures for Extending Coverage to Certain Devices and Related Services. 60 FR 48419 (September 19, 1995). 1995.
27 HHS. Scope of subpart and definitions. CMS, ed. 42 CFR 405.201. 2002.
28 HHS. FDA categorization of investigational devices. CMS, ed. 42 CFR 405.203. 2002.
29 HHS. Coverage of a non-experimental/investigational (Category B) device. CMS, ed. 42 CFR 405.205. 2002.
30 HHS. Services related to a noncovered device. CMS, ed. 42 CFR 405.207. 2002.
31 HHS. Payment for a non-experimental/investigational (Category B) device. CMS, ed. 42 CFR 405.209. 2002.
32 HHS. Procedures for Medicare contractors in making coverage decisions for a non-experimental/investigational (Category B) device. CMS, ed. 42 CFR 405.211. 2002.
33 HHS. Re-evaluation of a device categorization. CMS, ed. 42 CFR 405.213. 2002.
34 HHS. Confidential commercial and trade secret information. CMS, ed. 42 CFR 405.214. 2002.
35 HHS. Particular Services Excluded from Coverage. CMS, ed. 42 CFR 411.15(o). 2005.
36 Aaron HJ, Gelband H, editors. Committee on Routine Patient Care Costs in Clinical Trials for Medicare Beneficiaries IoM, editor. Extending Medicare reimbursement in clinical trials. Washington, D.C. National Academy Press. 2000.
37 Peters WP, Rogers MC. Variation in approval by insurance companies of coverage for autologous bone marrow transplantation for breast cancer.[see comment]. N Engl J Med. 1994;330(7):473-477. [pmid: 8289855].
38 Carino T, Sheingold S, Tunis S, et al. Using clinical trials as a condition of coverage: lessons from the National Emphysema Treatment Trial. Clinical Trials. 2004;1(1):108-114. discussion 115-21. [pmid: 16281466].
39 Excellus. (Excellus, Inc.). A rational clinical trial payment policy: Lesson from the use of bone-marrow transplantation for metastatic breast cancer. 2001. May. 2001.
40 Fleming ID, Fleming ID. Clinical trials for cancer patients. The community practicing physician's perspective. Cancer. 1990;65(10 Suppl):2388-2390. [pmid: 2334879].
41 Anonymous. Evaluation of emerging technologies for coronary revascularization. Participants in the National Heart, Lung, and Blood Institute Conference on the Evaluation of Emerging Coronary Revascularization Technologies. Circulation. 1992;85(1):357-361. [pmid: 1728468].
42 Gross CP, Wong N, Dubin JA, et al. Enrollment of older persons in cancer trials after the medicare reimbursement policy change. Arch Intern Med. 2005;165(13):1514-1520. [pmid: 16009867].
43 Unger JM, Coltman CA Jr, Crowley JJ, et al. Impact of the year 2000 Medicare policy change on older patient enrollment to cancer clinical trials. Journal of Clinical Oncology. 2006;24(1):141-144. [pmid: 16330670].
44 Kelahan AM. Dissemination of information on legislative mandates and consensus-based programs addressing payment of the costs of routine care in clinical trials through the World Wide Web.[see comment]. Cancer. 2004;100(6):1238-1245. [pmid: 15022292].
45 Martel C, Li Y, Lara P. Cancer clinical trial (CCT) accrual patterns: A prospective re-evaluation of barriers to enrollment following passage of legislation requiring third-party payer coverage of CCT costs in California. 2003 ASCO Annual Meeting. 2003. [Abstract No. 2112].
46 Miller R. Does coverage of renal intervention hinder trials? Stakeholders disagree. Health News Daily. 2007.
47 Mitka M, Mitka M. Regulations, payment affect stroke research. JAMA. 2007;297(12):1304-1305. [pmid: 17392230].
48 Vogelzang NJ, Richards JM, Vogelzang NJ, et al. Third-party reimbursement issues during a phase I trial of interleukin-2. Journal of the National Cancer Institute. 1989;81(7):544-545. [pmid: 2784171].
49 Hill K, Ross J, Egilman D, et al. The ADVANTAGE Seeding Trial: A review of internal documents. Ann Intern Med. 2008;149:251-258. [pmid: 18711155].
50 Wilensky GR, Wilensky GR. Developing a center for comparative effectiveness information.[see comment]. Health Aff (Millwood). 2006;25(6):w572-w585. [pmid: 17090555].
51 HarrisInteractive. Misconceptions and lack of awareness greatly reduce recruitment for cancer clinical trials. Health Care News. 2001.
52 Bleyer A, Montello M, Budd T. Young adults with leukemia in the United States: Lack of clinical trial participation and mortality reduction during the last decade. Journal of Clinical Oncology. 2004;22:6623.
53 Kuhn HB. Town hall meeting regarding the effect of coverage and payment on clinical research study participation and retention, September 20, 2007. Federal Register. 2007;72(164):48650.
54 CMS. National Coverage Determination for Routine Costs in Clinical Trials (310.1). 2007. Available at: http://www.cms.hhs.gov/mcd/viewncd.asp?ncd_id=310.1&ncd_version=2&basket=ncd%3A310%2E1%3A2%3ARoutine+Costs+in+Clinical+Trials. Date Accessed: August 26, 2009.
55 CMS. Presentations from September 20 town hall meeting. 2007;Vol. 2008.
56 CMS. Transcript from September 20 town hall meeting. 2007;Vol. 2008.
57 Murthy VH, Krumholz HM, Gross CP. Participation in cancer clinical trials: race-, sex-, and age-based disparities.[see comment]. JAMA. 2004;291(22):2720-2726. [pmid: 15187053].
58 Gross CP, Murthy V, Li Y, et al. Cancer trial enrollment after state-mandated reimbursement.[see comment]. Journal of the National Cancer Institute. 2004;96(14):1063-1069. [pmid: 15265967].
59 Mills EJ, Seely D, Rachlis B, et al. Barriers to participation in clinical trials of cancer: a meta-analysis and systematic review of patient-reported factors. Lancet Oncology. 2006;7(2):141-148.
60 Hansen KJ, Edwards MS, Craven TE, et al. Prevalence of renovascular disease in the elderly: a population-based study.[see comment]. Journal of Vascular Surgery. 2002;36(3):443-451. [pmid: 12218965].
61 Hirsch AT, Haskal ZJ, Hertzer NR, et al. ACC/AHA 2005 guidelines for the management of patients with peripheral arterial disease (lower extremity, renal, mesenteric, and abdominal aortic): executive summary a collaborative report from the American Association for Vascular Surgery/Society for Vascular Surgery, Society for Cardiovascular Angiography and Interventions, Society for Vascular Medicine and Biology, Society of Interventional Radiology, and the ACC/AHA Task Force on Practice Guidelines (Writing Committee to Develop Guidelines for the Management of Patients With Peripheral Arterial Disease) endorsed by the American Association of Cardiovascular and Pulmonary Rehabilitation; National Heart, Lung, and Blood Institute; Society for Vascular Nursing; TransAtlantic Inter-Society Consensus; Vascular Disease Foundation. Journal of the American College of Cardiology. 2006;47(6):1239-1312. [pmid: 16545667].
62 White CA, Jaffey J, Magner P. Cost of applying the K/DOQI guidelines for bone metabolism and disease to a cohort of chronic hemodialysis patients.[see comment]. Kidney International. 2007;71(4):312-317. [pmid: 17183248].
63 Himmelfarb J. Chronic kidney disease and the public health: gaps in evidence from interventional trials. JAMA. 2007;297(23):2630-2633. [pmid: 17579231].
64 Holohan TV. Extracranial-intracranial bypass to reduce the risk of ischemic stroke. CMAJ Canadian Medical Association Journal. 1991;144(11):1457-1465.
65 Jennett B. Surgery to prevent stroke. High hopes and deep disappointment. International Journal of Technology Assessment in Health Care. 1989;5(3):443-457. [pmid: 10303912].
66 NIH. Public Law 103-43: Heath Revitalization Act of 1993. Department of Health and Human Services, ed. 1993.
67 Bolen S, Tilburt J, Baffi C, et al. Defining "success" in recruitment of underrepresented populations to cancer clinical trials: moving toward a more consistent approach. Cancer. 2006;106(6):1197-1204. [pmid: 16453333].