# Examination of Randomized Controlled Trial Evidence

## A Why treat overweight and obesity?

The recommendation to treat overweight and obesity is based not only on the previously presented evidence that shows overweight is associated with increased morbidity and mortality, but also on randomized controlled trial (RCT) evidence that weight loss reduces risk factors for disease. Thus, weight loss may help control diseases worsened by overweight and obesity and may also decrease the likelihood of developing these diseases. The evidence meeting the panel's inclusion criteria is presented in the following section in the form of evidence statements with a corresponding rationale for each statement. The details of the studies reviewed but not discussed here are provided in [Appendix II].

Many of the RCTs examined by the panel included the use of pharmacotherapy for weight loss. When the panel began its deliberations in 1995, two weight loss drugs, fenfluramine and dexfenfluramine, were being used widely for long-term weight loss, i.e., 14 million prescriptions were given out over 1½ years. However, as of September 1997, the Food and Drug Administration (FDA) requested the voluntary withdrawal of these drugs from the market due to a reported association between valvular heart disease and the use of dexfenfluramine and fenfluramine alone or combined with phentermine [761]. In November 1997, the FDA approved the drug sibutramine hydrochloride monohydrate for the management of obesity, including weight loss and maintenance of weight loss when used in conjunction with a reduced-calorie diet. Thus, at the present time only one weight loss drug is available for long-term weight loss. (Note: FDA approval for orlistat is pending a resolution of labeling issues and results of Phase III trials.) However, due to rapidly evolving information regarding the use of pharmacotherapy for weight loss, the panel decided to present (below) their critique of those pharmacotherapy trials meeting their criteria for consideration.

### 1 Blood Pressure

To evaluate the effect of weight loss on blood pressure and hypertension, 76 articles reporting the results of RCTs were potentially eligible for inclusion. Sixty articles included lifestyle trials that studied diet and/or physical activity, and 16 articles were of pharmacotherapy trials. Dietary interventions included low-calorie diets and diets that promoted macronutrient composition changes, such as amount and type of dietary fat. Physical activity, when included, was used to help promote increased energy expenditure. These trials did not always control for other dietary factors that lower blood pressure, such as dietary salt, and the degree to which those taking the blood pressure measurements were blinded to the patient's change in weight.

Of the 35 lifestyle RCT articles deemed acceptable, 16 included hypertensive patients [346–361], and 19 were conducted in individuals with normal or high-normal blood pressure [362–380].

#### Lifestyle Trials in Hypertensive Patients

##### 1.a.(1) Evidence Statement

Weight loss produced by lifestyle modifications reduces blood pressure in overweight hypertensive patients. Evidence Category A.

Rationale: A 1987 meta-analysis [381] covering five of the acceptable studies [351, 352, 356–358] in hypertensive patients concluded that weight loss accomplished by dietary interventions significantly lowered blood pressure. In hypertensive patients, 10 kg (22 lb) of weight loss was associated with an average reduction of 7 mm Hg systolic and 3 mm Hg diastolic blood pressure compared with controls [381].

Since publication of this meta-analysis in 1987, almost all relevant studies have reported that weight loss reduces blood pressure or the need for medication in hypertensive patients: [346–348, 350, 352–361]

- The Trial of Antihypertensive Interventions and Management (TAIM), conducted in hypertensive individuals not taking medication for 6 months, reported that, compared with controls, a mean net weight reduction of 4.7 kg (10.4 lb) reduced systolic and diastolic blood pressure by 2.8 mm Hg and 2.5 mm Hg, respectively; [355] the effects on blood pressure were equivalent to drug therapy among those participants who lost 4.5 kg (9.9 lb) or more [360].
- One study in older (age 60 to 80 years) hypertensive adults whose blood pressure medication was withdrawn (Trial of Nonpharmacologic Interventions in the Elderly, TONE) showed that after 2 years, mean net weight loss of nearly 4 kg (9 lb) resulted in more participants free of trial endpoints (occurrence of high blood pressure, resumption of blood pressure medication, or occurrence of a cardiovascular-clinical complication [39.2 percent versus 26.2 percent]) [382]. Furthermore, blood pressure control was similar for men and women and for African-Americans and whites [353].
- In other studies of primarily middle-aged hypertensive adults, compared with controls, weight loss significantly reduced a return to hypertension medication at 1 year [354] and at 4 to 5 years [348, 359].
- The Multiple Risk Factor Intervention Trial, which recruited 12,866 high-risk men, 30 percent of whom had hypertension, delivered an integrated intervention addressing several lifestyle behaviors and included weight loss as an important component. Significant reductions in systolic and diastolic blood pressure were found over 6 years compared with the usual care group and were directly related to weight loss: 1 kg (2.2 lb) of weight loss was associated with a reduction of 0.4 mm Hg systolic and 0.3 mm Hg diastolic blood pressure in men not taking antihypertensive medications. The effect was slightly lower for men taking antihypertensive medications.
- Only one RCT conducted in hypertensive patients reported no significant change in blood pressure despite weight loss of 3.3 kg (7.3 lb) [351].
- Another study conducted in hypertensive individuals suggested that weight loss reduced blood pressure only when sodium intake was also reduced [349]. This finding was not consistent with a prior study of hypertensive patients [358] and has not been corroborated in subsequent larger trials conducted in nonhypertensive individuals [378, 379].

##### 1.a.(2) Evidence Statement

Weight loss produced by lifestyle modifications reduces blood pressure in overweight nonhypertensive individuals. Evidence Category A.

Rationale: A semiquantitative review [383] covering four of the acceptable studies [363, 366, 372, 374] in nonhypertensive individuals concluded that weight loss through dietary interventions significantly lowered blood pressure. In nonhypertensives, excluding one outlier trial that showed very large reductions in blood pressure [372], 1 kg (2.2 lb) of weight loss was associated with a reduction of 0.45 mm Hg in both systolic and diastolic blood pressure. Since this review, published in 1991, almost all relevant studies have reported that weight loss reduces blood pressure in nonhypertensive individuals [364, 365, 367–371, 373, 375–380, 384].

The Trials of Hypertension Prevention Phase 1 (TOHP I) and Phase 2 (TOHP II) are among the larger, well-designed randomized trials, having follow-up rates exceeding 90 percent. They followed the participants for 18 months [378] and 3 to 4 years [379]. The sample size of the weight loss intervention arms ranged from approximately 300 (TOHP I) to 600 (TOHP II). The populations were diverse, consisting of 30 to 35 percent women and 15 to 18 percent African-Americans, and were recruited from 10 centers in TOHP I and 9 centers in TOHP II. Results from both TOHP I and TOHP II demonstrated that weight loss reduced blood pressure and the incidence of hypertension. Compared with controls, in both trials 10 kg (22 lb) of weight loss was associated with a reduction of 7 mm Hg systolic and 5 to 6 mm Hg diastolic blood pressure at 18 months. At 36 months, systolic and diastolic blood pressure was reduced by 6 and 4 mm Hg, respectively, for every 10 kg of weight loss [379]. In addition, weight loss reduced the incidence of hypertension at 18 months by 20 to 50 percent [378, 379] and at 3 years by 19 percent [379]. Secondary analyses from TOHP I [376] and analyses under way from TOHP II [385] demonstrated that the greater the weight loss the greater the blood pressure reduction, and as long as weight loss was maintained, blood pressure remained reduced. One study that focused on older African-American diabetics showed that weight loss of 2.4 kg (5.3 lb) at 6 months resulted in a reduction of 3.9 and 4.0 mm Hg systolic and diastolic blood pressure [362]. Only one study in nonhypertensive individuals [368] showed inconsistent results, where weight reduction decreased systolic (significant) and diastolic (nonsignificant) blood pressure at 12 months in women but not in men. Another study [377] showed short-term (3 months) blood pressure reduction but no longer-term (9 months) blood pressure reduction despite maintenance of weight loss of 9 kg (19.8 lb) [384].

#### 1.b Pharmacotherapy Trials

Evidence Statement

Weight loss produced by most weight loss medications (except for sibutramine) and adjuvant lifestyle modifications is accompanied by reductions in blood pressure. Evidence Category B.

To determine the effects of pharmacological therapy on weight loss and subsequent changes in blood pressure levels, 10 RCT articles were examined [386–395]. Weight loss studies using pharmacotherapy were conducted predominantly in white women and assumed that dietary changes were uniform in the active drug and placebo groups. All of these studies had a placebo-control group for which dietary recommendations for weight loss were provided; weight loss also occurred in the placebo group. No studies examined whether weight loss using pharmacotherapy results in blood pressure reductions similar to weight loss produced by diet therapy, nor were the results compared with a pure control group with no weight loss. In addition, none of the studies that examined the effect of pharmacotherapy on blood pressure controlled for weight loss. In general, the use of phentermine, fenfluramine, and dexfenfluramine resulted in similar or better weight loss than that seen in the control or placebo group, and reductions in systolic and diastolic blood pressure were concomitantly similar to or better than those observed in the diet plus placebo group [386, 390–393, 395]. However, one study on dexfenfluramine [394] showed increased blood pressure compared to controls, even though weight loss was greater with dexfenfluramine than with placebo. Another study showed blood pressure lowering consistent with weight reduction produced by dexfenfluramine in women with upper-body obesity, but not in women with lower-body obesity [387]. In a combined summary of data on orlistat presented at the FDA Endocrinologic and Metabolic Drugs Advisory Committee Meeting (held in Bethesda, Maryland, in May 1997), only a small decrease in systolic (approximately 2 mm Hg) and diastolic (approximately 1 mm Hg) blood pressure was observed compared to the placebo [388]. In a study of sibutramine, a net weight loss at 3 months of approximately 2 kg (4.4 lb) did not result in lower blood pressure compared with placebo controls [389]. Eleven double-blind placebo-controlled trials lasting from 12 to 52 weeks showed that sibutramine is associated with mean increases in systolic blood pressure of 1 to 3 mm Hg, in diastolic pressure of 1 to 2 mm Hg, and mean increases in pulse rate of 3 to 5 beats per minute relative to placebo. In hypertensive obese patients, the mean change in blood pressure was the same in the sibutramine group and the placebo group; both dropped. Systolic pressure decreased 5.4 mm Hg in the sibutramine group and 5.8 mm Hg in the placebo group, while the diastolic drop was 5.9 mm Hg and 3.7 mm Hg, respectively. At the FDA recommended doses, 45 percent of patients had an increase, 35 percent had a decrease, and 20 percent had no change in blood pressure [389].

#### 1.c Abdominal Fat

Evidence Statement

Limited evidence suggests that decreases in abdominal fat reduce blood pressure in overweight nonhypertensive individuals, although this has not been shown to be independent of weight loss. Evidence Category C.

Rationale: Five RCTs [365, 369, 373, 375, 377] testing the effects of weight loss on blood pressure also measured abdominal fat by waist circumference or by dual-energy X-ray absorptiometry. In all five studies, waist circumference was reduced along with weight, and blood pressure was decreased. These studies were not designed to test whether reduction in abdominal fat reduces blood pressure independent of weight loss.

#### 1.d Fitness

Evidence Statement

Increased aerobic activity to increase cardiorespiratory fitness reduces blood pressure independent of weight loss. Evidence Category A.

Rationale: Seven RCTs testing the effects of weight loss on blood pressure in overweight and obese individuals also had measures of cardiorespiratory fitness, as measured by maximal oxygen uptake [346, 363, 369, 375, 377, 380]; or submaximal heart rate tests [365]. Weight loss was accompanied by increased fitness, primarily if the intervention included increased physical activity or physical activity combined with diet [346, 363, 375, 377, 380]. These studies were not designed to test whether increased cardiorespiratory fitness reduces blood pressure independent of weight loss in overweight and obese adults. By contrast, in 3 meta-analyses of 68 controlled studies of physical activity conducted in normotensive and hypertensive individuals, obesity was not an outcome measure nor was it included in the eligibility criteria. These meta-analyses showed that aerobic exercise to increase cardiorespiratory fitness significantly reduces blood pressure independent of or in the absence of weight loss [396–398].

RECOMMENDATION

Weight loss is recommended to lower elevated blood pressure in overweight and obese persons with high blood pressure. Evidence Category A.

### 2 Serum/Plasma Lipids and Lipoproteins

Sixty-five RCT articles were evaluated for the effect of weight loss on serum/plasma concentrations of total cholesterol, low-density lipoprotein (LDL)-cholesterol, very low-density lipoprotein cholesterol, triglycerides, and high-density lipoprotein (HDL)-cholesterol. Studies were conducted on individuals over a range of overweight and lipid levels. Weight loss in 52 of these trials was induced by various lifestyle modifications, including diet modification (reducing calories, or saturated fat and cholesterol, or both) and increased physical activity.

#### 2.a Lifestyle Trials

Evidence Statement

Weight loss produced by lifestyle modifications reduces serum triglycerides and increases HDL-cholesterol, and generally produces some reductions in serum total cholesterol, and LDL-cholesterol. Evidence Category A.

Rationale: Fourteen RCT articles that studied the effects of diet and/or physical activity on lipids were reviewed [365, 368, 370, 373, 380, 384, 399–406]. Table III-1 summarizes RCTs in which diet alone was used to produce weight loss. Entries under percentage change were calculated as follows: the percentage change (value at the end of study minus the value at baseline, divided by the value at baseline) was determined for the intervention group and the control group; the percentage change for the control group was then subtracted from the percentage change for the intervention group, giving the numerical value presented. When a run-in period was used, the “baseline” subtracted was the value at the end of the run-in, which was when the intervention began.

Table III-1 Weight Reduction by Diet Alone

| | Percentage Change
Study | N, Sex, and Duration | Weight Loss | TC | TG | LDL-C | HDL-C
Dengel [399] | 28M experimental | -12 | -9 | -36 | -9 | -3
| 14M control
| 9 months
Hellenius [365] | 40M experimental | BMI | -1 | -2 | -3 | +2
| 39M control | -2
| 6 months
Jalkanen [400] | 24 experimental (wt) | -5 | -7 | -28 | — | +8
| 22 experimental (lipid)
| 25 control (wt)
| 22 control (lipid)
| 12 months
Karvetti [368] | 71F experimental | -6 | -2 | — | — | +12
| 76F control
| 12 months
| 22M experimental | -11 | 0 | — | — | +27
| 20M control
| 12 months
Marniemi [402] | 37 (27F/10M) mixed diet | -13 | -4 | -41 | — | +18
| 42 (32F/10M) control
| 12 months
| 31 (23F/8M) lactovegetarian | -11 | -4 | -21 | — | +10
| 42 (32F/10M) control
| 12 months
Puddey [370] | 22M experimental | -8 | -7 | -27 | — | +9
| 20M control
| 18 weeks
Simkin-Silverman [373] | 253F experimental | -7 | -8 | -11 | -9 | +4
| 267F control
| 6 months
Svendsen [384] | 50F experimental | -13 | -18 | -44 | -22 | +3
| 20F control
| 12 weeks
Wood [380] | 40M experimental | -7 | -5 | -21 | -5 | +6
| 40M control
| 12 months
| 31F experimental | -7 | -7 | -5 | -8 | -7
| 39F control
| 12 months
Wood [406] | 42M experimental | -8 | -2 | -22 | -3 | +13
| 42M control
| 12 months

TC= Total Cholesterol

TG= Triglycerides

BMI= Body Mass Index

LDL-C= Low-Density Lipoprotein Cholesterol

HDL-C= High-Density Lipoprotein Cholesterol

Reductions in body weight varied from 5 to 13 percent compared to the control group. The following changes in plasma lipids and lipoproteins were observed: total cholesterol, 0 to -18 percent; triglycerides, -2 to -44 percent; LDL-cholesterol, -3 to -22 percent; and HDL-cholesterol, -7 to +27 percent. Most of the trials were of sufficient duration to ensure that these changes were not the result of acute caloric deficit.

Table III-2 summarizes RCTs in which diet plus physical activity or physical activity alone was used to produce weight loss. Entries under percentage change were calculated as for Table III-1. Similar changes were observed as for diet alone, although there was perhaps a more consistent trend for all the lipid parameters with the combination of diet and physical activity and with physical activity alone.

Table III-2 Weight Reduction by Diet Plus Physical Activity or Physical Activity Alone

| | Percentage Change
Study | N, Sex, and Duration | Weight Loss | TC | TG | LDL-C | HDL-C
Hellenius [365] | Diet+physical activity | BMI | -5 | -12 | -4 | -1
| 39M experimental | -4
| 39M control
| 6 month
| Physical activity only | BMI | 0 | -11 | 0 | +2
| 39M experimental | -2
| 39M control
| 6 months
King [401] | Physical activity only | BMI | — | -6 | +2 | -1
| 40M high intensity group | -1
| 41M control
| 12 months
| Physical activity only | BMI | — | 0 | -1 | +1
| 42M high intensity home | -1
| 41M control
| 12 months
| Physical activity only | BMI | — | -14 | 0 | +3
| 45M low intensity | -4
| 41M control
| 12 months
| Physical activity only | BMI | — | +1 | -4 | +1
| 34F high intensity group | +2
| 34F control
| 12 months
| Physical activity only | BMI | — | -2 | +3 | 0
| 35F high intensity home | 0
| 34F control
| 12 months
| Physical activity only | BMI | — | +4 | +3 | 0
| 29F low intensity | -2
| 34F control
| 12 months
Nilsson [403] | Diet+physical activity | BMI | -3 | -4 | -3 | -1
| 30 (24M/6F) experimental | -2
| 29 (22M/7F) control
| 12 months
Ronnemaa [404] | Physical activity only | -3 | -6 | -3 | -5 | +2
| 13 (8M/5F) experimental
| 12 (7M/5F) control
| 4 months
Schuler [405] | Diet+physical activity | -5 | -10 | -7 | -10 | +3
| 56M experimental
| 57M control
| 12 months
Svendsen [384] | Diet+physical activity | -14 | -17 | -35 | -26 | 0
| 48F experimental
| 20F control
| 12 weeks
Wood [380] | Diet+physical activity | -11 | -4 | -46 | -2 | +17
| 39M experimental
| 40M control
| 12 months
| Diet+physical activity | -9 | -5 | -18 | -8 | +5
| 42F experimental
| 39F control
| 12 months

TC= Total Cholesterol

TG= Triglycerides

BMI= Body Mass Index

LDL-C= Low-Density Lipoprotein Cholesterol

HDL-C= High-Density Lipoprotein Cholesterol

#### 2.b Pharmacotherapy Trials

Evidence Statement

Weight loss produced by weight loss medications and adjuvant lifestyle modifications produces no consistent change in blood lipids. Evidence Category B.

Rationale: The effects of pharmacological therapy on weight loss and subsequent changes in total serum cholesterol levels were evaluated by examining eight RCTs [386, 390–393, 395, 407, 408] (Table III-3). The four trials of dexfenfluramine showed no consistent effects on total cholesterol; three trials showed decreases in triglycerides ranging from 14 to 40 percent and two trials showed increases in HDL-cholesterol of 8 percent in women to 27 percent in men. One trial of phentermine plus fenfluramine showed a 24 percent decrease in triglycerides and a slight change in HDL-cholesterol [395]. The trial of orlistat showed a decrease in total cholesterol and an increase in triglycerides, while the trial of fluoxetine showed the opposite [407, 408]. Other RCTs using orlistat have shown a modest improvement in lipids with weight loss [388].

Table III-3 Weight Reduction by Drug Therapy

| | Percentage Change
Study | N, Sex, and Duration | Weight Loss | TC | TG | LDL-C | HDL-C
Bremer [386] | Dexfenfluramine | -6 | -14 | -40 | -9 | +15
| 12 (8M/4F) experimental
| 14 (8M/6F) control
| 12 weeks
Mathus-Vliegen [391] | Dexfenfluramine | -4 | +7 | -14 | — | —
| 17 experimental
| 18 control
| 12 months
O'Connor [392] | Dexfenfluramine | -6 | +5 | -26 | — | +27M
| 27 (6M/21F) experimental | | | | | +8F
| 24 (14M/10F) control
| 6 months
Pfohl [393] | Dexfenfluramine | -2 | -3 | +26 | — | —
| 19 experimental
| 15 control
| 12 months
Weintraub [395] | Fen/Phen | -13 | -6 | -24 | -2 | -1
| 53 Fen/Phen
| 51 placebo
| 34 weeks
Drent [407] | Orlistat | -2 | -2 | +8 | — | —
| 20 (3M/17F) Orlistat
| 19 (3M/16F) placebo
| 12 weeks
O'Kane [408] | Fluoxetine | -6 | +9 | -25 | — | —
| 7 Fluoxetine
| 9 placebo

TC= Total Cholesterol

TG= Triglycerides

BMI= Body Mass Index

LDL-C= Low-Density Lipoprotein Cholesterol

HDL-C= High-Density Lipoprotein Cholesterol

In a combined summary of data presented at the FDA Endocrinologic and Metabolic Drugs Advisory Committee Meeting (held in Bethesda, Maryland, in September 1996), use of sibutramine, which resulted in a greater net weight loss of 2.4 kg (5.3 lb) at 4 months, also resulted in modestly lower levels of total cholesterol, LDL-cholesterol, and triglycerides, along with slightly higher HDL-cholesterol levels, compared to placebos [389].

#### 2.c Abdominal Fat

Evidence Statement

Limited evidence suggests that decreases in abdominal fat correlate with improvements in the lipid profile of overweight individuals, although these improvements have not been shown to be independent of weight loss. Evidence Category C.

Rationale: Four RCTs testing the effects of weight loss on blood lipids also included measures of abdominal fat, as measured by waist circumference [365, 373, 375, 399]. In each study, waist circumference was reduced along with weight, and blood lipids were improved. These studies were not designed to test whether reductions in abdominal fat reduce blood lipids independent of weight loss. However, evidence exists from epidemiologic observational studies that abdominal fat is related to an adverse lipid profile, including higher levels of total cholesterol, LDL-cholesterol, and triglycerides, and lower levels of HDL-cholesterol [409, 410].

#### 2.d Fitness

Evidence Statement

Increased aerobic activity to increase cardiorespiratory fitness favorably affects blood lipids, particularly if accompanied by weight loss. Evidence Category A.

Rationale: Nine RCTs testing the effects of weight loss on lipoproteins measured cardiorespiratory fitness, as measured by maximal oxygen uptake [369, 375, 380, 384, 399, 401, 404–406]. Weight loss was accompanied by increased fitness if the intervention included increased physical activity or physical activity combined with diet [375, 380, 401, 404–406]. These studies were not designed to test whether increased cardiorespiratory fitness reduces blood lipids independent of weight loss in overweight and obese adults. However, considerable evidence exists that aerobic exercise decreases triglycerides and total cholesterol and may increase HDL-cholesterol in men and women, particularly if accompanied by weight loss [411].

RECOMMENDATION

Weight loss is recommended to lower elevated levels of total cholesterol, LDL-cholesterol and triglycerides and to raise low levels of HDL-cholesterol in overweight and obese persons with dyslipidemia. Evidence Category A.

### 3 Impaired Glucose Tolerance and Diabetes

Forty-nine articles of RCTs were reviewed to evaluate the effect of weight loss on fasting blood glucose and fasting insulin. Studies were conducted in individuals with normal blood glucose levels (fasting plasma glucose < 115 mg/dL [< 6.4 mmol/L]), in individuals with impaired glucose tolerance (fasting plasma glucose of < 140 mg/dL [7.8 mmol/L] or 2 hours postprandial plasma glucose of ≥ 140 to < 200 mg/dL [7.8-11.1 mmol/L]), or in individuals with diabetes (fasting plasma glucose of > 140 mg/dL or 2 hours postprandial plasma blood glucose ≥ 200 mg/dL).^*^

* The reviewed articles used the “old” definitions of the American Diabetes Association (ADA) for impaired glucose tolerance and diabetes. As of November 1997, the new ADA definitions define “impaired fasting glucose” as those individuals having a fasting plasma glucose of 110 to 125 mg/dL, and “diabetes” as those individuals having a fasting plasma glucose of ≥ 126 mg/dL or 2 hours postprandial plasma glucose of ≥ 200 mg/dL.

The methods of weight loss included diet, physical activity, or both; behavior therapy; and pharmacotherapy. The dietary interventions included low calorie and very low calorie, and those that promoted changes in diet composition, such as amount and type of dietary fat. Physical activity varied from controlled individualized exercise programs to informal group sessions coupled with behavior therapy and dietary changes. The degree of blinding of outcome measures was not always well described, nor was there a systematic consideration of concurrent effects of changes in medication or adherence to medication among diabetic patients enrolled in these weight reduction studies.

Of the 17 RCT articles considered acceptable, 10 included normoglycemic individuals [367, 373, 386, 387, 390–393, 403, 412], 2 included patients with impaired glucose tolerance [70, 369], and 5 included patients with type 2 diabetes [362, 404, 408, 413, 414].

#### 3.a Lifestyle Trials

Evidence Statement

Weight loss produced by lifestyle modifications, reduces blood glucose levels in overweight and obese persons without type 2 diabetes, and reduces blood glucose levels and HbA_1c_ in some patients with type 2 diabetes. Evidence Category A.

Rationale: Nine RCTs examined lifestyle therapy [70, 362, 367, 369, 373, 403, 404, 412, 413]. Five RCTs among normoglycemic overweight individuals examined the effects of behavior therapy or lifestyle change on weight loss. Changes in fasting glucose or fasting insulin are used as secondary outcome measures. Improvements in the levels of fasting insulin with weight loss ranged from 18 to 30 percent. While weight loss was maintained, improvements were observed for fasting glucose, fasting insulin, and glucose and insulin levels during oral glucose tolerance testing compared to controls [367, 373, 403, 412].

Three RCTs of lifestyle modifications were conducted among overweight diabetic patients [362, 404, 413]. One RCT of diet and physical activity in African-Americans aged 55 to 79 years with type 2 diabetes showed a 2.4 kg (5.3 lb) weight loss at 6 months compared to the usual-care control group. The intervention group also decreased HbA_1c_ by 2.4 percentage units at 6 months [362]. In another study, weight loss of 5 kg (11 lb) through diet resulted in a reduction of HbA_1c_ by 2 percentage units at 6 months compared with the controls [413]. At 1 year, the difference in weight loss between the two groups was reduced, and diabetic control was similar in each group. In the third study, weight loss, through physical activity in 25 type 2 diabetes patients randomly assigned to physical activity (13 patients) or control (12 patients) groups, was associated with improved HbA_1c_ [404].

One RCT of 530 individuals in China with impaired glucose tolerance compared the effects of diet, physical activity, and diet plus physical activity on the incidence of diabetes. The data were analyzed for the group as a whole and for the lean and overweight groups separately. The overweight individuals in the diet and diet plus physical activity groups lowered their BMIs, while the lean individuals did not. After 6 years, the cumulative incidence rates of diabetes were significantly lower in all three intervention groups than they were in the controls (43.8 percent in the diet group, 41.1 percent in the physical activity group, 46 percent in the diet plus physical activity group, and 67.7 percent in the controls). This was true also if only the overweight persons were included in the analysis [70].

#### 3.b Pharmacotherapy Trials

Evidence Statement

Weight loss produced by weight loss medications has not been shown to be any better than weight loss through lifestyle modification for improving blood glucose levels in overweight or obese persons both with and without type 2 diabetes. Evidence Category B.

Rationale: Eight RCT articles considered the effects of pharmacotherapy on weight loss and subsequent changes in blood glucose [386, 387, 390–393,408, 414].

Six trials in nondiabetic individuals reported weight loss with anorexiant drugs [386, 387,390–393]. One study of 75 subjects with refractory obesity showed that those taking dexfenfluramine had a significantly better improvement in their blood glucose levels as compared to placebo controls [390]. Another trial showed that after 6 months on dexfenfluramine, fasting serum insulin levels fell from 105 at baseline to 89 at 6 months, but glucose levels did not decrease [392]. This study was difficult to interpret. Four other RCTs of dexfenfluramine failed to show any significant differences between the active drug and placebo groups for glucose or insulin, despite significant differences in weight reduction [386, 387, 391, 393].

Among diabetic patients, there were two trials of anorexiant drugs. One trial of dexfenfluramine compared with standard clinic practice showed significantly greater weight loss at 3 months but not at 6 or 12 months [414]. Weight loss at 3 months was 3.4 kg (7.5 lb) in the dexfenfluramine group and 1.59 kg (3.5 lb) in the clinic group. At 6 months, the weight loss was 3.13 kg (6.9 lb) in the dexfenfluramine group and 1.70 kg (3.7 lb) in the clinic group. By 1 year, both groups had regained some weight. Despite more than a 1 kg (2.2 lb) difference of weight between the dexfenfluramine group and the control group, there were no significant differences between groups in changes from baseline for HbA_1c_ at any of the follow-up times (3, 6, or 12 months). In the trial of fluoxetine, those patients on 60 mg of fluoxetine daily compared with the placebo group had significant weight loss at 6 months, a finding that was associated with improvements in glucose and HbA_1c_. At 12 months, these differences were no longer significant [408]. The RCTs of orlistat showed a drop in both fasting glucose and HBA_lc_ in diabetic patients on a combination therapy of lifestyle change and orlistat for weight loss [388].

#### 3.c Abdominal Fat

Evidence Statement

Decreases in abdominal fat improve glucose tolerance in overweight individuals with impaired glucose tolerance, although this has not been shown to be independent of weight loss. Evidence Category C.

Rationale: Two RCTs testing the effects of weight loss on changes in glucose tolerance and insulin also had measures of abdominal fat, as measured by waist circumference [369, 373]. In each study, waist circumference was reduced along with weight loss and glucose tolerance improved. Neither study was designed to test whether reductions in waist circumference improved glucose tolerance or diabetic control independent of weight loss.

Evidence exists from observational studies that abdominal fat is related to impaired glucose tolerance or type 2 diabetes independent of BMI. For instance, a few studies have found a significant relationship between abdominal fat loss and improvement in glucose tolerance and insulin action [415–418].

#### 3.d Fitness

Evidence Statement

Increased cardiorespiratory fitness improves glucose tolerance in overweight individuals, but no evidence shows this relationship to be independent of weight loss. Evidence Category C.

Rationale: Two RCTs that examined the effects of weight loss on glucose tolerance in older men [369] and in persons with diabetes [404] also had measures of VO_2_ max (oxygen consumption) as a measure of fitness. In both studies, physical activity resulted in a net weight loss of approximately 2.3 to 2.5 kg (2 to 3 percent) and increased VO_2_ max by 9 to 18 percent. In one study [419] most measures of glucose tolerance improved, whereas in the other study [369] only 2-hour insulin improved. Neither study was designed to test whether increased fitness improves glucose tolerance independent of weight loss.

RECOMMENDATION

Weight loss is recommended to lower elevated blood glucose levels in overweight and obese persons with type 2 diabetes. Evidence Category A.

### 4 Decreases in Abdominal Fat With Weight Loss

Evidence Statement

Weight loss is associated with decreases in abdominal fat, as measured by waist circumference. Evidence Category A.

Rationale: Six acceptable RCTs on weight loss that measured waist circumferences all show that weight loss is associated with reductions in waist circumference [365, 369, 373, 375, 384, 399]. Waist circumference is commonly used as a surrogate measure for abdominal visceral fat [420, 421]. Although no RCTs examined changes in visceral fat per se, one observational study [422] showed significant decreases in visceral fat with a mean weight loss of 12.9 kg (28.4 lb).

In addition, many observational and non-RCT interventional studies have reported that weight loss caused by a variety of treatments reduces abdominal visceral fat levels [417, 423–428]. Fat located in the abdominal region is associated with greater health risks than that in peripheral regions, e.g., the gluteal-femoral area [155–159, 429, 430]. Many studies used the waist-to-hip ratio as the measure of abdominal fat; however, the panel considered waist circumference to be a better marker of abdominal fat content than the waist-to-hip ratio. For more information on abdominal fat, see Section 4.B.

## B What Treatments are Effective?

A variety of modalities may be used to treat overweight and obesity. To assess their effectiveness on weight loss, loss of abdominal fat, and cardiorespiratory fitness, evidence from RCTs was examined. These trials considered dietary therapy, physical activity, combined therapy, behavior therapy, pharmacotherapy, and surgery. The details of the studies reviewed and subsequently not included are provided in [Appendix II].

### 1 Dietary Therapy

Eighty-six RCT articles evaluated the effectiveness of many different diets on weight loss: low-calorie diets (LCDs), very low-calorie diets (VLCDs), vegetarian, American Heart Association guidelines and the National Cholesterol Education Program's Step I diet with caloric restriction, and other low-fat regimens with varying combinations of macronutrients. The trials that included participants who were not overweight were rejected. Some trials were done in patient populations with diabetes, hypertension, or hyperlipidemia. Many of the trials do not mention whether concomitant physical activity programs were promoted, and many do not give information about the behavioral approaches that were used to deliver the diet or physical activity intervention. Approximately 60 percent of the trials are equal to or greater than 6 months in duration.

#### 1.a Low-Calorie Diets

Evidence Statement

LCDs can reduce total body weight by an average of 8 percent over 3 to 12 months. Evidence Category A.

Rationale: Thirty-four RCT articles examined the impact on weight loss of an LCD consisting of approximately 1,000 to 1,200 kilocalories/day. Many of these LCDs also promoted low fat intake as a practical way to reduce calories. Twenty-five RCT articles covered interventions lasting 6 or more months [346–348, 350, 354, 355, 359, 363–366, 368, 369, 373, 375, 378–380, 399, 400, 406, 413, 431–433].

Another nine RCTs lasted 12 to 21 weeks [349, 351, 356, 370, 371, 377, 384, 434, 435].

All of the studies, regardless of the length of the intervention, showed that LCDs result in weight loss. From the 25 RCT articles with a duration of ≥ 6 months, compared to controls, LCDs brought about a mean weight loss of approximately 8 percent of body weight over a period of 6 months and up to 1 year. The nine studies with an intervention lasting from 3 months up to 6 months also averaged approximately 8 percent weight loss compared to controls. Four studies that included a long-term weight loss and maintenance intervention lasting 3 to 4.5 years reported an average weight loss of 4 percent over the long term [348, 359, 366, 379].

Evidence Statement

LCDs resulting in weight loss effect a decrease in abdominal fat. Evidence Category A.

Four RCTs testing the effects of LCDs alone on weight loss also had measures of abdominal fat, as measured by waist circumference [365, 369, 375, 399]. The studies showed consistently that waist circumference decreases along with weight loss produced by LCDs. After 6 to 12 months, LCDs resulted in a mean weight loss of as little as 0.3 BMI unit to as much as 11 kg (24.3 lb) body weight, and a concomitant reduction in waist circumference of 1.5 to 9.5 cm compared to controls.

Evidence Statement

No improvement in cardiorespiratory fitness as measured by VO_2_ max appears to occur in overweight or obese adults who lose weight on LCDs without increasing physical activity. Evidence Category B.

Rationale: Ten RCTs examined whether weight loss through diet alone without increased physical activity had an effect on cardiorespiratory fitness as measured by VO_2_ max when compared to controls with no weight loss. Four RCTs reported no improvement in VO_2_ max [363, 375, 399, 435], while six RCTs reported an improvement [346, 369, 380, 384, 406, 432]. In three of the six studies, improvement in those on the LCD was shown because the control group had a large decrease in VO_2_ max [346, 406, 432]. In all six studies that showed improvement, VO_2_ max was expressed as ml/kg/min rather than liters/min. Because the ratio of ml O_2_/kg/min increases with weight loss alone and not necessarily from an improvement in oxygen uptake, results from studies reporting VO_2_ max in terms of ml O_2_/kg/min are equivocal. The three studies that reported VO_2_ max as liters/min consistently showed no improvement from diet alone [375, 399, 435].

#### 1.b Very Low-Calorie Diets

Evidence Statement

VLCDs produce greater initial weight loss than LCDs. However, the long-term (> 1 year) weight loss is not different from that of the LCD. Evidence Category A.

Four RCTs compared VLCDs to LCDs [436–439]. The VLCDs provided about 400 to 500 kcal/day, whereas the LCDs provided approximately 1,000 to 1,500 kcal/day. During the active phase, VLCDs were given exclusively for 12 to 16 weeks and then were followed by LCDs for a total duration ranging from 24 weeks to 5 years. The participants in these trials were primarily women who were extremely obese.

VLCDs either alone or, usually, combined with behavioral therapy, promoted weight loss of approximately 13 to 23 kg (28.7 to 50.7 lb) during the active phase of the VLCD intervention, compared to 9 to 13 kg (19.8 to 28.7 lb) with LCDs. In three of the four studies, VLCDs resulted in 4 to 12 kg (8.8 to 26.5 lb) greater weight loss than the LCDs at the end of the active phase [436–438]. Over the medium term of 6 to 12 months, weight loss on the VLCDs ranged from 1.1 kg (2.4 lb) to as much as 10.4 kg (22.9 lb) greater than weight loss on LCDs. One study did not show a particular advantage of VLCD over LCD either during the active phase or at 24 weeks [439]. After 1 year, there was no long-term advantage of VLCDs over LCDs [436, 437].

#### 1.c Lower-Fat Diets

Evidence Statement

Although lower-fat diets without targeted caloric reduction help promote weight loss by producing a reduced caloric intake, lower-fat diets coupled with total caloric reduction produce greater weight loss than lower-fat diets alone. Evidence Category A. Lower-fat diets produce weight loss primarily by decreasing caloric intake. Evidence Category B.

Rationale: Nine RCTs testing the effects of diet on weight loss promoted diets that varied in fat and caloric content [317, 364, 369, 434, 440–444]. Lower-fat diets varied from 20 to 30 percent of calories from fat, and calories ranged from 1,200 to 2,300 calories.

Three RCTs, all 6 months or greater in duration, promoted lower-fat diets with ad libitum caloric intake. Two of the three RCTs reported that lower-fat diets with ad libitum energy intake resulted in a reduction in caloric intake of 85 kcal and 300 kcal [317, 444], and all three RCTs produced greater weight loss by 1 to 3.9 kg (2.2 to 8.6 lb), compared to a higher-fat diet [317, 441, 444]. The third RCT had a large disparity in baseline caloric intake between the two diet groups, making the reported caloric intakes at the end of the study difficult to compare [441].

Three RCTs compared lower-fat diets with targeted caloric reduction to lower-fat diets alone, and all three found that weight loss is greater in the lower-fat diet with caloric reduction than with the lower-fat diet alone [369, 434, 442].

When similar caloric levels occur between lower-fat and higher-fat diets, similar amounts of weight loss were reported in two studies [364, 443], whereas one study showed 1.8 kg (4 lb) greater weight loss on the lower-fat compared with the higher-fat diet, despite similar reported calorie levels [440].

Taken together, these studies show that lower-fat diets ranging from 20 to 30 percent of calories can contribute to lower caloric intake even when caloric reduction is not the focus of the intervention [317, 444], but when LCDs are targeted with lower-fat diets, better weight loss is achieved [369, 434, 442]. However, there is little evidence that lower-fat diets (per se) cause weight loss independent of caloric reduction.

RECOMMENDATION

LCDs are recommended for weight loss in overweight and obese persons. Evidence Category A. Reducing fat as part of an LCD is a practical way to reduce calories. Evidence Category A.

### 2 Physical Activity

Twenty-four RCT articles were reviewed for the effect of physical activity on weight loss, abdominal fat (measured by waist circumference), and changes in cardiorespiratory fitness (VO_2_ max). Thirteen articles were deemed acceptable [346, 363, 365, 369, 375, 401, 404, 406, 432, 434, 445–447]. Only one of these RCTs compared different intensities and format with a control group, although the goal was to increase physical activity and not specifically to produce weight loss [401]. Results from this trial were subsequently reported after 2 years, but these no longer included the control group [447]. One additional study did not have a no-treatment control group, but compared three active treatment groups with each other: diet only, exercise only, and combination exercise plus diet [448].

Most RCTs described the type of physical activity as cardiovascular endurance activities in the form of aerobic exercise such as aerobic dancing, brisk walking, jogging, running, riding a stationary bicycle, swimming, and skiing, preceded and followed by a short session of warmup and cool down exercises. Some physical activity programs also included unspecified dynamic calisthenic exercises [363, 369, 406, 446].

The intensity of the physical activity was adapted to each individual and varied from 60 to 85 percent of the individual's estimated maximum heart rate, or was adjusted to correspond to approximately 70 percent of maximum aerobic capacity (VO_2_ max). The measure of physical fitness included VO_2_ max. The frequency of physical activity varied from three to seven sessions a week and the length of the physical activity session ranged from 30 to 60 minutes. Some physical activity programs were supervised, and some were home-based. Adherence to the prescribed physical activity program was recorded and reported in some studies and not mentioned in others. Most studies did not estimate the caloric expenditure from the physical activity or report calorie intake. The duration of the intervention varied from 16 weeks to 1 year; six articles reported on trials that lasted at least 1 year [346, 363, 375, 401, 406, 432].

Evidence Statement

Physical activity, i.e., aerobic exercise, in overweight and obese adults results in modest weight loss independent of the effect of caloric reduction through diet. Evidence Category A.

Rationale: Twelve RCT articles examined the effects of physical activity, consisting primarily of aerobic exercise, on weight loss compared to controls [346, 363, 365, 369, 375, 401, 404, 406, 432, 434, 445, 446]. Ten of the 12 RCT articles reported a mean weight loss of 2.4 kg (5.3 lb) (or 2.4 percent of weight) [363, 369, 375, 406, 419, 432, 434] or a mean reduction in BMI of 0.7 kg/m^2^ (2.7 percent reduction) [346, 365, 401] in the exercise group compared to the control group. In three of these ten studies, the weight loss was < 2 percent of body weight (< 2 kg) (4.4 lb) [369, 375, 434]. In contrast, two RCTs showed no benefit on weight from exercise, reporting weight gain in the exercise group compared to the control group [445, 446]. In one of these studies, the control group received only diet advice but nevertheless lost 9 kg (19.8 lb), whereas the exercise group lost only 7 kg (15.4 lb) [445]. In the second study, there was a total of only 10 participants, all having noninsulin-dependent diabetes mellitus, and the control group lost 3 kg (6.6 lb) whereas the exercise group lost only 2 kg (4.4 lb) [446]. A meta- analysis of 28 publications of the effect on weight loss of exercise compared to diet or control groups showed that aerobic exercise alone produces a modest weight loss of 3 kg (6.6 lb) in men and 1.4 kg (3.1 lb) in women compared to controls [449].

Ten articles reported on RCTs that had a diet-only group in addition to an exercise-only group [346, 363, 365, 369, 375, 406, 432, 434, 445, 448]. In every case except one [365], the exercise-only group did not experience as much weight loss as the diet-only group. The diet-only group produced approximately 3 percent, or 3 kg (6.6 lb), greater weight loss than the exercise-only group.

No single study examined the length of the intervention in relation to the weight loss outcome. Only one study compared the effect on maximum oxygen uptake of different intensities and formats of physical activity over a 1-year follow-up [401] and 2-year follow-up period [447]. Better adherence over 1 year was found if the exercise was performed at home rather than in a group setting, regardless of the intensity level. Subsequently, the different exercise groups were compared with each other over the longer term (2 years), and better long-term adherence was found in the higher intensity home-based exercise group compared to the lower intensity home-based or higher intensity group-based exercise groups [447].

The question of whether physical activity enhances long-term maintenance of weight loss has not been formally examined in RCTs. Examination of long-term weight loss maintenance produced by physical activity interventions compared with diet-only interventions cannot easily be compared between RCTs because of numerous differences between studies with respect to design, sample size, intervention content and delivery, and characteristics of the study population samples. However, a number of analyses of observational and post hoc analyses of intervention studies have examined whether physical activity has a beneficial effect on weight. Cross-sectional studies have generally shown that physical activity is inversely related to body weight [450–454] and rate of weight gain with age [455]. Longitudinal studies with 2 to 10 years of follow-up results have observed that physical activity is related to less weight gain over time [456–459], less weight gain after smoking cessation in women [460], and weight loss over 2 years [461]. In addition, post hoc analyses of several weight loss intervention studies reported that physical activity was a predictor of successful weight loss [454, 462, 463].

The results of these RCTs showed that physical activity produces only modest weight loss and observational analyses from other studies suggest that physical activity may play a role in long-term weight control and/or maintenance of weight loss.

Evidence Statement

Physical activity in overweight and obese adults modestly reduces abdominal fat. Evidence Category B.

Rationale: Only three RCTs testing the effect of physical activity on weight loss also had measures of abdominal fat as assessed by waist circumference [365, 369, 375]. One study demonstrated that physical activity reduced waist circumference compared with the control group [365], and another study showed a small effect on waist circumference (0.9 cm) in men but not women [375]. One study in men showed a small increase in waist circumference [369]. Weight loss was modest in all of these studies. These studies were not designed to test the effects of physical activity on abdominal fat independent of weight loss.

However, several large studies in Europe [464], Canada [453], and the United States [465–468] reported that physical activity has a favorable effect on body fat distribution. These studies showed an inverse association between energy expenditure through physical activity and several indicators of abdominal obesity, such as waist circumference and waist-to-hip and waist-to-thigh circumference ratios.

Evidence Statement

Physical activity in overweight and obese adults increases cardiorespiratory fitness independent of weight loss. Evidence Category A.

Rationale: Eleven RCT articles testing the effect of physical activity alone on weight loss in men and women also included measures of cardiorespiratory fitness, as measured by maximal oxygen uptake (VO_2_ max) [346, 363, 369, 375, 401, 404, 406, 432, 434, 445, 446]. All 11 showed that physical activity increased maximum oxygen uptake in men and women in the exercise groups by an average of 14 percent (ml/kg body weight) to 18 percent (L/min). Even in studies with modest weight loss (< 2 percent), physical activity increased VO_2_ max by an average of 12 percent (L/min) to 16 percent (ml/kg) [369, 375, 434].

One study that compared different formats and intensities of physical activity on VO_2_ max reported that improvement in VO_2_ max was related to adherence to the physical activity regime. In that study, the lower-intensity program was equally effective on VO_2_ max as a higher-intensity program, largely as a result of different levels of adherence [401].

The results of the RCTs strongly demonstrate that physical activity increases cardiorespiratory fitness in overweight and obese individuals.

RECOMMENDATION

Physical activity is recommended as part of a comprehensive weight loss therapy and weight maintenance program because it: (1) modestly contributes to weight loss in overweight and obese adults (Evidence Category A), (2) may decrease abdominal fat (Evidence Category B), (3) increases cardiorespiratory fitness (Evidence Category A), and (4) may help with maintenance of weight loss (Evidence Category C).

### 3 Combined Therapy (Diet and Physical Activity)

Twenty-three RCT articles investigated the effects on body weight of a combination of a reduced calorie diet with increased physical activity. The control groups used diet alone or physical activity alone.

Of the 15 studies deemed acceptable, each of them compared the combined intervention with diet alone [346, 365, 375, 377, 380, 384, 434, 435, 445, 448, 469–473], and 6 of them also compared the combined intervention to physical activity alone [346, 365, 375, 434, 448, 474]. The studies varied in terms of the length of the active intervention period as well as the length of the follow-up. Many of the programs lasted for more than 6 months, and five studies had intervention or follow-up data for at least 1 year [346, 375, 380, 445, 473]. Two studies included patients with type 2 diabetes [470, 473]. Participants in the diet and physical activity group most often participated in supervised group-based physical activity consisting of 30- to 60-minute sessions 3 times a week, and they were encouraged to maintain a maximum heart rate between 60 and 80 percent. There were three diet components: general dietary advice, caloric reduction of 500 to 1,000 kcal per day, or a diet containing 1,200 kcal per day.

Evidence Statement

The combination of a reduced calorie diet and increased physical activity produces greater weight loss than diet alone or physical activity alone. Evidence Category A.

Rationale: Of the 15 RCT articles, 12 observed that the combined diet and physical activity group had a mean greater weight loss of 1.9 kg (4.2 lb) and a mean greater BMI reduction of 0.4 (range of 0.3 to 0.5) than the diet-alone group [346, 365, 375, 377, 380, 384, 434, 435, 448, 469, 470, 473].

One study compared different forms of physical activity in combination with diet and found that, compared to diet alone, the greatest weight loss occurred when the combination intervention included both aerobic and resistance training: 0.9 kg (2 lb) greater weight loss than aerobic exercise plus diet [435]. Another study reported that participants receiving resistance training in combination with diet had 2.2 and 5.0 kg (4.9 and 11 lb) greater weight loss than the diet-alone group after 24 and 48 weeks, respectively [469].

Five of the six studies that compared combined intervention with physical activity alone observed that the combined intervention group had a 5.3 kg (11.7 lb) (range of 3.6 to 6.2 kg) (7.9 to 13.7 lb) greater weight loss and 0.9 change in BMI unit than the physical activity-alone group [346, 365, 375, 434, 448]. This greater weight loss was significant in three studies [365, 375, 448].

Three RCTs compared the longer-term versus the shorter-term effects of the combination of physical activity and diet versus diet alone [384, 469, 473]. All three studies found that the combination resulted in approximately 1.5 to 3 kg (3.3 to 6.6 lb) greater weight loss than diet alone over the longer term of 9 months to 2 years.

Evidence Statement

The combination of a reduced calorie diet and increased physical activity produces greater reductions in abdominal fat than either diet alone or physical activity alone, although it has not been shown to be independent of weight loss. Evidence Category B.

Rationale: Three RCTs [365, 375, 471]that examined the combined effect of diet and physical activity on weight loss also had measures of abdominal fat, as measured by waist circumference. Two of the three RCTs showed that the combination intervention resulted in greater reduction in waist circumference than diet alone in men [365, 375] and (only one) in women [375]. In the other RCT, no differences in reduced waist circumference were observed [471]. Of the three RCTs comparing combination therapy to physical activity alone, one study reported a greater waist reduction of 2.7 to 3.8 cm in women and men, respectively [375], and by less than 1 cm in another study [365]. The effects of combination therapy on abdominal fat in these studies are not separable from the effects on weight loss.

Evidence Statement

A combination of a reduced calorie diet and increased physical activity improves cardiorespiratory fitness as measured by VO_2_ max when compared to diet alone. Evidence Category A.

Rationale: Nine RCTs examined the effect of a combination of diet and physical activity on fitness compared to diet alone [346, 375, 377, 380, 434, 435, 445, 448, 475]. In most studies, the physical activity was in the range of 60 to 80 percent VO_2_ max. All nine RCTs showed that a combination of diet and physical activity improved cardiorespiratory fitness, as measured by VO_2_ max, more than diet alone, whether reported relative to body mass in ml O_2_/kg/min or in absolute values by ml O_2_/min [346, 375, 377, 380, 434, 435, 445, 448, 475]. Studies of longer duration tended to show the greatest improvement. This improvement was significant in six of the studies [346, 375, 377, 380, 434, 448].

RECOMMENDATION

The combination of a reduced calorie diet and increased physical activity is recommended, since it produces weight loss, decreases abdominal fat, and increases cardiorespiratory fitness. Evidence Category A.

### 4 Behavior Therapy

Behavior therapy constitutes those strategies, based on learning principles such as reinforcement, that provide tools for overcoming barriers to compliance with dietary therapy and/or increased physical activity. Two questions are important in assessing the effect of behavior therapy in the treatment of overweight and obesity. First, does behavior therapy provide additional benefits above and beyond the other weight loss approaches—diet, physical activity, or drug therapy? Second, are there behavioral strategies that are more effective than others?

#### 4.a Additional Benefits Beyond Other Weight Loss Approaches

Thirty-six RCT articles were examined to evaluate whether behavior therapy provides additional benefits beyond other weight loss approaches. The acceptable RCTs compared behavior therapy plus another weight loss strategy to that weight loss strategy without behavior therapy.

Evidence Statement

Behavior therapy, when used in combination with other weight loss approaches, provides additional benefits in assisting patients to lose weight short term (1 year). Evidence Category B. No additional benefits are found at 3 to 5 years in the absence of continued intervention. Evidence Category B.

Rationale: Four RCTs addressed the question of whether behavior therapy, in order to reinforce a healthy diet, provides additional benefits above and beyond other weight loss approaches. Three studies compared behavior therapy plus dietary intervention to a dietary intervention alone [436, 476, 477]. No studies were found that examined the added benefit of behavior therapy when combined with either physical activity or diet and physical activity. One study was found that compared behavior therapy to drug therapy [478].

One study compared 36 obese women in one of three groups of 12 participating in a 16-week intervention: (1) individual counseling; (2) group counseling; and (3) group counseling plus behavior therapy. All groups lost weight at the end of treatment, and there were no significant differences among the groups. By the 1-year follow-up, participants in groups 1 and 3 were equally successful in maintaining weight loss, while most participants in group 2 regained most of their weight [476].

Other studies examined the effect of VLCD alone and in combination with behavior therapy [436, 477]. Subjects were randomly assigned to either: (1) VLCD alone; (2) behavior therapy plus LCD (1,000 to 1,200 kcal), denoted as the behavior therapy-alone group; or (3) VLCD plus behavior therapy (combined treatment). They were assessed at the end of treatment and at 1- and 5-year follow-ups. At the end of treatment, and at the 1-year follow-up, weight loss was significantly greater for the combination group as compared to the other two groups. About one-third of those receiving behavior therapy (either in combination with an LCD or VLCD) were able to maintain their full end-of-treatment weight loss at 1 year, compared to only 5 percent of those in the diet-alone group. By the 5-year follow-up, the mean weight loss was not significantly different across groups.

Thus, although the weight loss results of behavioral treatment in combination with either an LCD or VLCD were quite good at the end of treatment and at the 1-year follow-up, they were not maintained by 5 years. These results may well have been due to the infrequent practice of the behavioral strategies by the subjects. Wadden and colleagues recommended that patients participate in a 6- to 12-month weight maintenance program after weight loss (which subjects did not do in the study described above), and that if they experience a gain of ≥5 kg (11 lb) which they cannot reverse on their own, that they should reenter a weight loss therapy program.

One study assessed the short- and long-term weight loss of behavior therapy, fenfluramine, or a combination of the two in 120 obese women [478]. Patients in the drug group and those in the combined drug plus behavior therapy group lost significantly more weight than did the group that received behavior therapy only and the control group; the drug-only group and combination group did not differ from each other at the end of the 6-month treatment. However, at the 1-year follow-up, significantly less weight was regained by the patients in the behavior-therapy-only group compared to the combined treatment group and the pharmacotherapy group, resulting in significantly better overall net weight loss. Results of this study suggest that the various interventions had different effects at the end of treatment and at follow-up.

To summarize, three of the four studies demonstrated that behavior therapy, when used in conjunction with other weight loss approaches, was more effective in reducing weight or delaying weight regain, either at the end of treatment or at the 1-year follow-up or both [476–478]. Behavior therapy was not better in its effect on weight loss at the 5-year follow-up.

No RCTs examined the additional effect of behavior therapy combined with diet and physical activity on cardiorespiratory fitness or abdominal fat.

#### 4.b Comparison of Behavior Therapy Strategies

Another way to examine the efficacy of behavior therapy in the treatment of overweight and obesity is to evaluate studies that compare various behavioral techniques with one another. Of 31 RCTs that compared one or more behavioral interventions, 19 were deemed acceptable.

Evidence Statement

No one behavior therapy appeared superior to any other in its effect on weight loss; rather, multimodal strategies appeared to work best and those interventions with the greatest intensity appeared to be associated with the greatest weight loss. Evidence Category A.

Of the 19 RCTs, 17 produced weight loss [367, 476, 479–493]. Behavioral strategies to reinforce changes in diet and physical activity in obese adults produce weight loss in the range of 10 percent of baseline over 4 months to 1 year. The greatest amount of weight loss was usually observed in less than 12 months of the intervention; however, weight loss was observed for up to 2½ years in some studies. Multimodal strategies worked best, and the intensity (number of contacts and duration) and degree (albeit difficult to discern in some of these studies) of a particular reinforcement were most related to weight loss. Although initial therapy proved successful, it also appeared that when behavioral therapy ceased, weight was regained on average, but not all subjects relapsed back to baseline levels. Ten of the 19 studies were based on at least 1-year results [367, 476, 479, 480, 484, 486–488, 492, 493].

Fourteen trials compared different behavior therapy strategies. Two trials compared cognitive behavior therapy techniques, specifically cognitive rehearsal, social pressure, and cue avoidance (see Glossary) with other behavior therapies [479, 480]. With regard to weight loss, cognitive rehearsal was no more effective than the group support or “social pressure” condition and was less effective than cue avoidance [480]. Another study indicated no clear benefits for cognitive rehearsal above and beyond other behavioral strategies [479]. One [483] of two studies that assessed the effect of monetary incentives reported greater weight loss [367, 483].

The effect of extending treatment in various ways was evaluated in several studies [486, 487, 489, 494]. One study evaluated 20 weeks versus 40 weeks of standard behavior therapy and found greater weight loss with the extended therapy that was maintained at 72 weeks [486]. Another study evaluated behavior therapy and the effect of a posttreatment therapist on weight loss [487]. The study evaluated the effect of extended treatment using therapist contact in general, therapist contact emphasizing social influence, and extended treatment emphasizing physical activity. The emphasis of physical activity plus social influence produced greater weight loss than not having contact emphasizing these components. Extended contact with a therapist produced about 10 kg (22 lb) greater weight loss than no extended contact, even over the long term. At 18 months, all strategies that combined behavior therapy with a post-treatment maintenance program yielded a significantly greater long-term weight loss than behavior therapy alone.

Another study examined the effect of extending cognitive behavior therapy for 3 months in addition to the initial 3 months of therapy for obese patients with binge eating disorder, and found that extended cognitive behavior therapy improved binge eating behavior, although not weight [494]. A pilot study of women with type 2 diabetes compared a 16-week group-behavioral weight loss program to the same group, but with three individualized motivational interviewing sessions added. Both groups demonstrated significant weight loss with the motivational group losing 5.5 kg (12.1 lb) on average and the standard behavioral group losing 4.5 kg (9.9 lb); there were no differences between the two. However, those in the motivational interviewing group demonstrated better attendance at meetings (attending on average 13.3 meetings versus 8.9 meetings), had significantly better glucose control, and recorded blood glucose and food diaries more frequently [489] than did members of the standard behavioral group.

A study that involved self-instruction plus incentives versus group instruction plus incentives demonstrated no effect of the group treatment on weight loss [481]. Weight loss was positively associated with attendance; however, mandatory attendance did not seem to increase program effectiveness and seemed to discourage attendance among men. The program was equally effective when implemented through either self-help materials or by professionals. Another study compared stimulus-narrowing during the reintroduction of food (achieved by providing prepackaged food) for those on VLCDs to providing regular food during the reintroduction [495]. They also compared reintroduction of foods based on progress in losing weight or maintaining weight loss versus a time-dependent basis. Neither strategy was helpful in maximizing weight loss or weight maintenance.

Two trials evaluated the impact of spousal involvement versus no spousal involvement in behavior therapy [488, 492]. One study found no overall differences in weight loss between those treated with spouses and those treated without spouses; however, women lost more weight when treated with a spouse, and men did better when treated alone (P < .01 at end of treatment; P < .06 at 1 year) [492]. Another study found a positive effect of spousal involvement on weight loss soon after treatment was completed; however, this effect had largely dissipated by the 3-year follow-up [488].

In summary, a variety of behavioral therapy strategies promote weight loss, with no one particular behavioral strategy having the greatest efficacy. Multimodal strategies with greater intensity appear to be most effective.

Evidence Statement

Long-term follow-up of patients undergoing behavior therapy shows a return to baseline weight in the great majority of subjects in the absence of continued behavioral intervention. Evidence Category B.

Rationale: Studies have shown that while weight loss is achieved, it is very difficult to maintain over a long period of time (1 to 5 years) in the absence of continued intervention [436, 477, 486, 491]. This emphasizes the great importance of continuing a maintenance program on a long-term basis.

Evidence Statement

Little evidence exists on the effect of behavior therapy in combination with diet and physical activity on cardiorespiratory fitness.

Rationale: One RCT examined the impact of different levels of behavior therapy in combination with diet and aerobic exercise on cardiorespiratory fitness [484]. Subjects were randomly assigned to one of three groups which varied in their degree of training in, and detailed application of, behavioral change principles (described as the basic, extended, and maximal behavioral therapy groups). All groups incorporated frequent intensive therapist contact, self-monitoring of behavior, regular objective assessment, and feedback of change in status. The three groups differed in the degree of emphasis given to behavioral self-management training, amount of detail provided on individual risk factors and overall coronary heart disease risk, and establishment of realistic short-term goals for coronary risk factor change. In terms of cardiorespiratory fitness, the group receiving the extended behavioral therapy and the group receiving the maximal behavior therapy showed improvements in VO_2_ max of 2.90 and 3.40 mL/kg/min, respectively, when compared with controls who received the basic behavior therapy. However, it is unlikely that behavior therapy caused these improvements independent of weight loss.

No RCT evidence exists on the effect of behavior therapy combined with diet and physical activity on changes in abdominal fat as measured by waist circumference.

RECOMMENDATION

Behavior therapy is a useful adjunct when incorporated into treatment for weight loss and weight maintenance. Evidence Category B.

Commentary: Do the same treatment approaches for overweight and obesity fit diverse patient populations?

Whether or not the same weight reduction program will accomplish equivalent weight change in ethnically diverse population groups can be questioned on theoretical grounds. Weight reduction programs address motivations and behaviors strongly influenced by sociocultural factors that vary with ethnicity [257, 496, 497]. Sociocultural factors may also influence the relative efficacy of behavioral programs in young, middle, and older adulthood; men or women; or any other patient groups where the motivations and lifestyle factors targeted may vary from those commonly assumed to be in operation. Innate or acquired physiological factors that affect energy metabolism may also influence the relative efficacy of behavioral weight reduction programs. For example, some cross-sectional comparisons have suggested that the relative weight loss achieved for a given degree of calorie restriction will be lower in African-Americans than whites because of a lower resting metabolic rate in African-Americans [498–501]. Another study suggests metabolic influences on weight loss in premeno- pausal versus postmenopausal women [502].

The diversity of populations in obesity treatment studies is limited, and there is not a coherent body of studies evaluating systematic differences in the outcomes of overweight and obesity treatment by age, socioeconomic status, or other participant characteristics that might be expected to influence outcome. However, the possibility of differences in the effectiveness of behavioral weight reduction approaches between African-Americans and whites has been suggested by reports from several intervention studies [360, 503–505]. In some of these trials, weight reduction was the only intervention; in other instances it was combined with sodium reduction or other dietary or lifestyle changes. Taken together, these studies suggest that, on average, within the same program, weight losses of African-Americans are less than those of their white counterparts, particularly among women. A formal analysis of this issue in two RCTs—the Hypertension Prevention Trial and Phase 1 of the Trials of Hypertension Prevention—suggested that the weight gain in control participants was also higher among African-Americans than whites, but, in women, the net weight loss (i.e., active intervention minus control) was still less in African-Americans. There is ample evidence to support explanations of this differential weight loss on the basis of cultural or behavioral factors related to program adherence [257]. However, data to evaluate the alternative or additional contribution of metabolic factors to this differential are lacking. To date, no published studies permit separation of metabolic and behavioral influences on the observed ethnic differences in weight loss. (Also see commentary on pages 89 to 91 under treatment guidelines.)

RECOMMENDATION

The possibility that a standard approach to weight loss will work differently in diverse patient populations must be considered when setting expectations about treatment outcomes. Evidence Category B.

### 5 Pharmacotherapy

Since 1995, the use of the prescription drugs fenfluramine or dexfenfluramine for weight loss had increased greatly to 14 million prescriptions in 1½ years. The increased interest in drug treatment of obesity derives from the poor long-term results often obtained with behavior therapy, including diet and physical activity, as noted earlier in this report. The rationale for the addition of drugs to these regimens is that a more successful weight loss and maintenance may ensue. However, as of September 1997, the FDA requested the voluntary withdrawal of fenfluramine and dexfenfluramine from the market, due to a reported association between valvular heart disease with the drugs dexfenfluramine and fenfluramine, alone or combined with phentermine [761]. In November 1997, the FDA provided clearance for marketing the drug sibutramine hydrochloride monohydrate for the management of obesity, including weight loss and maintenance of weight loss when used in conjunction with a reduced-calorie diet. Due to the rapidly evolving information regarding the use of pharmacotherapy for weight loss, the panel decided to present their critique of those pharmacotherapy trials meeting their criteria for consideration.

Forty RCT articles evaluated the effect of pharmacotherapy on weight loss. In most studies, advice or behavioral therapy promoting reduced energy intake and increased physical activity was included in all treatment arms, including the placebo group.

Drugs that have been evaluated alone or in combination for at least 1 year by RCTs are phentermine, d,l-fenfluramine, dexfenfluramine, sibutramine, and orlistat. Two reports addressing dexfenfluramine [390, 506] represent a subset of a larger multicenter trial, the International Dexfenfluramine Study (INDEX trial) [507]. Of the nine trials with dexfenfluramine, four had interventions of approximately 1 year, three of approximately 6 months, and two of 3 months. Most of the trials included a majority of white women, and some included persons with diabetes. Most of the trials have weight regain data. One RCT [508] evaluated the effect of dexfenfluramine versus placebo on patients who had been on an 8-week VLCD for an additional 24 weeks. One RCT [509] evaluated the effect of phentermine versus placebo on patients with osteoarthritis. One RCT [510] evaluated the effect of various doses of sibutramine on weight loss over a 24-week period. Two RCTs of 12 and 8 weeks in duration studied phenylpropanolamine versus placebo [511, 512]. One used phenylpropanolamine with diet [512], and the other with diet, exercise, and behavior therapy [511]. Phenylpropanolamine is available as an over-the-counter drug. The average weight loss after 8 weeks of treatment was 2.59 kg (5.7 lb) for the drug versus 1.07 kg (2.4 lb) for the placebo, a difference of 1.5 kg (3.3 lb) [511]. Short-term, but not long-term (over 1 year), effectiveness has been documented.

Evidence Statement

Pharmacotherapy, which has generally been studied along with lifestyle modification including diet and physical activity, using dexfenfluramine, sibutramine, orlistat, or phentermine/fenfluramine, results in weight loss in obese adults when used for 6 months to 1 year. Evidence Category B.

Rationale: Data reporting the results of 52 weeks of drug treatment are available only for dexfenfluramine, orlistat, phentermine, d,l-fenfluramine, and sibutramine. The effect on weight loss from these drugs after 1 year is modest: 2.6 kg (5.7 lb) difference on average between dexfenfluramine and placebo (9.8 kg [21.6 lb] versus 7.2 kg [15.9 lb], baseline weights of 98.0 kg [216 lb] and 96.6 kg [213 lb]) [507]. For sibutramine, a difference of 2.8 kg (6.2 lb) was seen at 1 year (4.4 kg [9.7 lb] versus 1.6 kg [3.5 lb]) [513]. In another study of sibutramine, the difference was a net loss of 5.5 kg (12.1 lb) at 24 weeks with a 20 mg dose [510]. In all of the weight loss studies that were up to 1 year in duration, the majority of the weight loss occurred in the first 6 months with a plateauing or actual increase in weight in the following 6 months [388, 389, 507, 514]. For orlistat, a difference of 2.2 kg (4.9 lb) (4.3 kg [9.5 lb] versus 2.1 kg [4.6 lb]) was found in a 16-week study [407]. After a 210-week study on phentermine and d,l-fenfluramine, participants averaged a weight loss of 1.4 kg (3.1 lb) from baseline weight at week 210 [395, 514].

There are no known pharmacologic agents whose specific effect is to reduce abdominal fat or to improve cardiorespiratory fitness. Any improvements in abdominal fat or fitness would be secondary to weight loss or other interventions.

Sibutramine is approved for long-term use. (Note: FDA approval of orlistat is pending a resolution of labeling issues and results of Phase III trials.) Such drugs can then be used as an adjunct to modifications in behavior, including diet and physical activity. Drugs should be discontinued if significant weight loss is not achieved, i.e., a loss of < 4 pounds in the first 4 weeks, or if serious adverse effects occur.

RECOMMENDATION

Weight loss drugs may only be used as part of a comprehensive weight loss program including diet and physical activity for patients with a BMI of ≥30 with no concomitant obesity-related risk factors or diseases, or for patients with a BMI of ≥27 with concomitant obesity-related risk factors or diseases. Evidence Category B.

### 6 Surgery

Fourteen RCTs compared the weight-reducing effect of different surgical interventions. They did not compare surgery versus no intervention. Because of the nature of the intervention, there is a reluctance to do such a randomized trial.

Evidence Statement

Surgical interventions in adults with a BMI ≥ 40 or a BMI ≥ 35 with comorbid conditions result in substantial weight loss. Evidence Category B.

Rationale: Of the 14 RCTs that examined the effect of surgical procedures on weight loss, 8 were deemed appropriate. All the studies included individuals who had a BMI of 40 kg/m^2^ or above, or a BMI of 35 to 40 kg/m^2^ with comorbidity; most of the study participants were women. Weight loss due to surgical intervention such as the gastric bypass ranged from 50 kg (110 lb) to as much as 100 kg (220 lb) over a period of 6 months to 1 year. Gastroplasty with diet had a favorable net outcome on weight loss after 2 years compared to diet alone [515]. Vertical-banded gastroplasty was more effective than horizontal-banded gastroplasty [516]. Gastric resection with a modest biliopancreatic diversion without intestinal exclusion resulted in significantly greater weight loss than conventional Roux-en Y gastric bypass; this long-limb modification of Roux-en Y gastric bypass was shown to be safe and effective in patients who were 200 lb or more overweight and did not cause additional metabolic sequelae or diarrhea [517].

The Swedish Obesity Study (SOS) [518], a non-RCT, found that gastric bypass produced greater weight loss than gastroplasty, 42.3 kg (93.3 lb) versus 29.9 kg (67 lb), at 1 year. The gastric bypass was deemed superior to gastroplasty or gastric partitioning in other RCTs as well [518–522]. The SOS also evaluated the correlation between stoma size and weight loss in patients assigned to gastric bypass or gastroplasty, and found no significant correlation in the gastric bypass group.

Comorbidity factors associated with weight loss showed improvement after surgery. One study showed that medical illnesses either improved (47 percent) or resolved (43 percent) in all but four patients (9 percent), and these four had unsatisfactory weight loss [517]. The Adelaide Study showed that 60 percent of the patients who initially had obesity-related comorbidity were free of medication for these comorbidities 3 years after surgery [519].

Extremely obese persons often do not benefit from the more conservative treatments for weight loss and weight maintenance. Obesity severely impairs quality of life, and these individuals are at higher risk for premature death [523]. The National Institutes of Health Consensus Development Conference consensus statement, “Gastrointestinal Surgery for Severe Obesity [523], ” concluded that the benefits outweigh the risks and that this more aggressive approach is reasonable in individuals who strongly desire substantial weight loss and have life-threatening comorbid conditions.

The effects of surgery on abdominal fat or cardiorespiratory fitness independent of weight loss are unknown. One small study demonstrated that surgery (adjustable silicone gastric banding) reduced abdominal visceral fat. No analyses were performed to examine whether visceral fat reduction was independent of weight loss [524]. There are no data on the effects of surgery on changes in cardiorespiratory fitness.

RECOMMENDATION

Surgical intervention is an option for carefully selected patients with clinically severe obesity (a BMI ≥40 or ≥35 with comorbid conditions) when less invasive methods of weight loss have failed and the patient is at high risk for obesity-associated morbidity and mortality. Evidence Category B.

### 7 Other Interventions for Overweight and Obesity Treatment

Other types of interventions considered for overweight and obesity treatment included acupuncture, herbal remedies, supplements, and hypnosis. However, these treatments did not fulfill the a priori inclusion criteria, and for that reason were not included in this review.