# Publication List

## Reports and Materials on Cardiovascular Health from the National Heart, Lung, and Blood Institute

Unless otherwise noted, contact the NHLBI Information Center for the price and availability of the publications listed below:

NHLBI Information Center

P.O. Box 30105

Bethesda, MD 20824-0105

nhlbiic@dgsys.com

Obesity and Physical Activity

Strategy Development Workshop for Public Education on Weight and Obesity--Summary Report. Summary of a 1992 workshop held to identify issues in educating the public, identifying priority audiences, approaches, and communications channels for weight and physical activity. Available at http: //www.nhlbi.nih.gov/nhlbi/ cardio/obes/prof/obeshc.htm

Methods for Voluntary Weight Loss and Control (National Institutes of Health Technology Assessment Conference). An edited summary of a 1992 NIH Technology Assessment Conference on American weight loss practices, success of methods of weight loss and control, short- and long-term benefits and adverse effects of weight loss, principles for selecting a weight loss and control strategy, and future directions for research. Available at http://text.nlm.nih.gov/ nih/ta/www/10.html

[Full proceedings available in Danford, D., Fletcher, S.W. Methods for Voluntary Weight Loss and Control, National Institutes of Health Technology Assessment Conference. Annals of Internal Medicine Supplement, 119(7pt2)641–770(1993).]

NIH Consensus Development Conference on Physical Activity and Cardiovascular Health. An edited summary of a 1995 NIH Consensus Development Conference which examined the accumulating evidence on the role of physical activity in the prevention and treatment of cardiovascular disease and its risk factors. Available at http: //odp.od.nih.gov/consensus/ statements/cdc/intros/physact_intro.html

[Full proceedings available from Leon, A. (ed.) Physical Activity and Cardiovascular Health: A National Consensus. Human Kinetics:1995.]

### High Blood Pressure

The Sixth Report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure (JNCVI). Provides guidance for primary care clinicians on the prevention, detection, treatment, and control of high blood pressure. Lifestyle modification and pharmacotherapy are discussed. Treatment algorithms and patient handouts are included.

Working Group Report on Hypertension in Diabetes. Guides clinicians in the care of persons with hypertension and diabetes. Addresses epidemiological, diagnostic, clinical consideration, and special concerns, such as kidney disease, sexual dysfunction, obesity, and pregnancy.

Working Group Report on Hypertension in the Elderly. Assists clinicians in their care of elderly patients with high blood pressure and health care professionals in hypertension control programs that serve the elderly. Presents the prevalence and epidemiology, benefits of antihypertensive therapy, detection and evaluation, therapy, and management considerations for the fastest growing special population in the United States.

Controlling High Blood Pressure in Older Women: Clinical Reference Manual. Assists clinicians in the care of older patients with high blood pressure, especially women. Presents the benefits of anithypertensive therapy, detection, evaluation, and treatment strategies. Includes charts to help clinicians improve patient adherence to therapy and select antihypertensive drug therapy.

### High Blood Cholesterol

Second Report of the Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults (ATP II). Provides guidelines for detecting, evaluating, and treating high blood cholesterol in adult patients. Discusses classification of blood cholesterol, patient evaluation, and dietary and drug treatment. Includes helpful tools for the clinician including a dietary questionnaire, menus, and patient handouts.

Cholesterol Lowering in the Patient with Coronary Heart Disease: Physician Monograph. Reviews the scientific evidence that cholesterol lowering in patients with coronary heart disease produces dramatic benefits. Provides guidance on implementing dietary and drug treatment and improving patient adherence to lowering cholesterol in the patient with coronary heart disease.

### Enhance your Patient Education with NHLBI Materials

#### Obesity and Physical Activity

Check Your Weight and Heart Disease I.Q. A true/false quiz that helps the public determine what they know about weight and heart disease. Correct answers are explained on the back of the quiz sheet.

Check Your Physical Activity and Heart Disease I.Q. Uncovers exercise myths and provides information on ways to improve heart health through physical activity.

Exercise and Your Heart: A Guide to Physical Activity. Provides your patients with information on the effects of physical activity on their heart, and practical guidelines for starting and staying on their own exercise program. The benefits, risks, and common myths about exercise are discussed, and tips and sample activity programs are included.

#### High Blood Pressure

High Blood Pressure: Treat It For Life. Helps patients take action against high blood pressure, by losing weight if overweight, increasing physical activity, choosing foods lower in salt and sodium, limiting alcohol, and taking medication as prescribed. Includes information for women taking birth control pills, older persons, African Americans, and people with diabetes or high blood cholesterol. A sample walking program, menu ideas, and recipes are included.

Eat Right to Help Lower Your High Blood Pressure. Presents practical information in an easy to read (5th grade level) conversational text brochure presented in large type with colorful illustrations. Helps patients reduce high blood pressure by losing weight, being more active, drinking less alcohol, and using less salt and sodium.

Facts About The DASH Diet. Describes the eating plan from the “Dietary Approaches to Stop Hypertension” (DASH) study, which was shown to lower blood pressure. The diet is rich in fruits, vegetables, and lowfat dairy products, and lower in saturated fat, total fat, and cholesterol. A full week's menu, recipes, and helpful tips are included.

Controlling High Blood Pressure: A Woman's Guide. Explains how high blood pressure affects women's health and tells the simple steps used to prevent and control high blood pressure, as well as the types of medication used to treat the condition. A table of generic names of blood pressure medications and a chart for recording blood pressure readings are given.

#### High Blood Cholesterol

So You Have High Blood Cholesterol. Gives patients the information on what they need to know about and what they need to do to lower their high blood cholesterol level. Diet, physical activity, weight loss strategies, and medications are discussed. Case studies highlight stategies for action.

Step by Step: Eating To Lower Your High Blood Cholesterol. Advises patients on how to make diet and lifestyle changes to lower their high blood cholesterol levels. Explains the Step I and Step II diets and gives practical tips for buying and preparing foods, eating out, increasing physical activity and selecting a weight loss program. Sample menus at two calorie levels and nutrient content tables of a wide variety of foods are included.

Eat Right to Lower Your High Blood Cholesterol. Provides practical information on dietary changes to high blood cholesterol in an easy-to-read (5th grade) conversation style. Includes shopping and cooking tips, sample menu and snack suggestions, and a tear-off shopping guide.

Live Healthier, Live Longer: Lowering Cholesterol for the Person With Heart Disease. Gives the patient with coronary heart disease information on how to lower high blood cholesterol through diet, physical activity and weight control to prevent future heart attacks and improve the quality of life. Practical information included on choosing foods lower in saturated fat, total fat, and cholesterol.

#### Multiple Risk Factors

Healthy Heart Handbook for Women. Tells women (both with and without heart disease) how to take action to make their hearts healthier. Topics include how to talk to the doctor, blood pressure and blood cholesterol, physical activity, weight loss, hormone replacement therapy, heart attack symptoms, and heart-healthy eating.

Package of Eight Easy-To-Read Booklets in Spanish and English on Preventing Heart Disease. Written especially for Latino families, these booklets include: Watch Your Weight, Stay Active and Feel Better, Cut Down on Fat--Not Taste, Take Steps--Prevent High Blood Pressure, Cut Down on Salt and Sodium, Learn Your Cholesterol Number, Protect Your Heart--Lower Your Blood Cholesterol, and Kick the Smoking Habit.

Delicious Heart-Healthy Latino Recipes (bilingual). Provides 23 traditional Latino recipes lower in calories, fat, saturated fat, cholesterol, and sodium.

Improving Cardiovascular Health in African Americans--Package of Seven Easy-To-Read Booklets. Written especially for African Americans, these booklets include: Lose Weight If You Are Overweight--Embrace Good Health, Stay Physically Active--Energize Yourself, Prevent High Blood Pressure--Protect Your Heart, Eat Less Salt and Sodium--Spice Up Your Life, Learn Your Cholesterol Number--Empower Yourself, Eat Foods Lower in Saturated Fat and Cholesterol--Be Heart Smart, Stop Smoking--Refresh Yourself.

Heart-Healthy Home Cooking--African American Style. Provides 20 favorite African American recipes lower in calories, fat, saturated fat, cholesterol, and sodium.

### Stay up-to-date on line—

- Visit the NHLBI website and find many of these publications on line at —www.nhlbi.nih.gov/nhlbi/nhlbi.htm.
- Learn of new publications as they become available by joining the NHLBI listserve.

### It's easy as 1, 2, 3!

1. Address an e-mail message to LISTSERV@LIST.NIH.GOV. No subject is necessary.
2. In the body of the message type in SUBSCRIBE NHLBIINFO.
3. A confirmation will be sent to you. When the confirmation is received, send a reply message and type “OK” in the body of the reply.