# Reference List

1 Kuczmarski R J, Carrol M D, Flegal K M, Troiano R P. Varying body mass index cutoff points to describe overweight prevalence among U.S. adults: NHANES III (1988 to 1994). Obes Res. 1997;5:542-548. [pmid: 9449138].
2 Brown CD, Donato KA, Obarzanek, E, et al. Body mass index and prevalence of risk factors for cardiovascular disease. Obes Res. 1998; submitted for publication.
3 Association of Life Insurance Medical Directors of America. Society of Actuaries. Blood Pressure Study, 1979. Chicago: The Society; 1980.
4 Stamler R, Stamler J, Riedlinger W F, Algera G, Roberts R H. Weight and blood pressure. Findings in hypertension screening of 1 million Americans. JAMA. 1978;240:1607-1610. [pmid: 691146].
5 Criqui M H, Mebane I, Wallace R B, Heiss G, Holdbrook M J. Multivariate correlates of adult blood pressures in nine North American populations: The Lipid Research Clinics Prevalence Study. Prev Med. 1982;11:391-402. [pmid: 7122431].
6 Dyer A R, Elliott P. The INTERSALT study: relations of body mass index to blood pressure. INTERSALT Co-operative Research Group. J Hum Hypertens. 1989;3:299-308. [pmid: 2810326].
7 Westlund K, Nicolaysen R. Ten-year mortality and morbidity related to serum cholesterol. A follow-up of 3,751 men aged 40–49. Scand J Clin Lab Invest Suppl. 1972;127:1-24. [pmid: 4640618].
8 Lew E A, Garfinkel L. Variations in mortality by weight among 750,000 men and women. J Chronic Dis. 1979;32:563-576. [pmid: 468958].
9 Larsson B, Bjorntorp P, Tibblin G. The health consequences of moderate obesity. Int J Obes. 1981;5:97-116. [pmid: 6971814].
10 Medalie J H, Papier C, Herman J B, et al. Diabetes mellitus among 10,000 adult men. I. 5-year incidence and associated variables. Isr J Med Sci. 1974;10:681-697. [pmid: 4851353].
11 Hubert H B, Feinleib M, McNamara P M, Castelli W P. Obesity as an independent risk factor for cardiovascular disease: a 26-year follow-up of participants in the Framingham Heart Study. Circulation. 1983;67:968-977. [pmid: 6219830].
12 Rexrode K M, Hennekens C H, Willett W C, et al. A prospective study of body mass index, weight change, and risk of stroke in women. JAMA. 1997;277:1539-1545. [pmid: 9153368].
13 Walker S P, Rimm E B, Ascherio A, Kawachi I, Stampfer M J, Willett W C. Body size and fat distribution as predictors of stroke among US men. Am J Epidemiol. 1996;144:1143-1150. [pmid: 8956626].
14 Stampfer M J, Maclure K M, Colditz G A, Manson J E, Willett W C. Risk of symptomatic gallstones in women with severe obesity. Am J Clin Nutr. 1992;55:652-658. [pmid: 1550039].
15 Khare M, Everhart J E, Maurer K R, Hill M C. Association of ethnicity and body mass index (BMI) with gallstone disease in the United States. Am J Epidemiol. 1995;141:S69.
16 Cicuttini F M, Baker J R, Spector T D. The association of obesity with osteoarthritis of the hand and knee in women: a twin study. J Rheumatol. 1996;23:1221-1226. [pmid: 8823696].
17 Hart D J, Spector T D. The relationship of obesity, fat distribution, and osteoarthritis in women in the general population: the Chingford Study. J Rheumatol. 1993;20:331-335. [pmid: 8474072].
18 Hochberg M C, Lethbridge-Cejku M, Scott W W Jr, Reichle R, Plato C C, Tobin J D. The association of body weight, body fatness and body fat distribution with osteoarthritis of the knee: data from the Baltimore Longitudinal Study of Aging. J Rheumatol. 1995;22:488-493. [pmid: 7783067].
19 Millman R P, Carlisle C C, McGarvey S T, Eveloff S E, Levinson P D. Body fat distribution and sleep apnea severity in women. Chest. 1995;107:362-366. [pmid: 7842762].
20 Young T, Palta M, Dempsey J, Skatrud J, Weber S, Badr S. The occurrence of sleep-disordered breathing among middle-aged adults. N Engl J Med. 1993;328:1230-1235. [pmid: 8464434].
21 Shepard J W Jr. Hypertension, cardiac arrhythmias, myocardial infarction, and stroke in relation to obstructive sleep apnea. Clin Chest Med. 1992;13:437-458. [pmid: 1521412].
22 Bostick R M, Potter J D, Kushi L H, et al. Sugar, meat, and fat intake, and nondietary risk factors for colon cancer incidence in Iowa women (United States). Cancer Causes Control. 1994;5:38-52. [pmid: 8123778].
23 Chute C G, Willett W C, Colditz G A, et al. A prospective study of body mass, height, and smoking on the risk of colorectal cancer in women. Cancer Causes Control. 1991;2:117-124. [pmid: 1873436].
24 Garland C, Shekelle R B, Barrett-Connor E, Criqui M H, Rossof A H, Paul O. Dietary vitamin D and calcium and risk of colorectal cancer: a 19-year prospective study in men. Lancet. 1985;1:307-309. [pmid: 2857364].
25 McGinnis J M, Foege W H. Actual causes of death in the United States. JAMA. 1993;270:2207-2212. [pmid: 8411605].
26 Broussard B A, Sugarman J R, Bachman-Carter K, et al. Toward comprehensive obesity prevention programs in Native American communities. Obes Res. 1995;3:2895-2975. [pmid: 8581789].
27 Najjar M F, Kuczmarski R J. Anthropometric data and prevalence of overweight for Hispanics: 1982-1984. National Center for Health Statistics. Vital Health Stat [11]. 1989;239:1-106. [pmid: 2786659].
28 World Health Organization. Physical status: the use and interpretation of anthropometry. Report of a WHO Expert Committee. World Health Organ Tech Rep Ser. 1995;854:1-452. [pmid: 8594834].
29 VanItallie TB, Lew EA. Overweight and Underweight. In: Lew EA, Gajewski J, eds. Medical Risks: Trends in Mortality by Age and Timed Elapsed. Vol 1. New York: Praeger; 1990: Chapter 13.
30 VanItallie T B. Health implications of overweight and obesity in the United States. Ann Intern Med. 1985;103:983-988. [pmid: 4062130].
31 Manson J E, Stampfer M J, Hennekens C H, Willett W C. Body weight and longevity. A reassessment. JAMA. 1987;257:353-358. [pmid: 3795418].
32 Troiano R P, Frongillo E A Jr, Sobal J, Levitsky D A. The relationship between body weight and mortality: a quantitative analysis of combined information from existing studies. Int J Obes Relat Metab Disord. 1996;20:63-75. [pmid: 8788324].
33 National Research Council. Committee on Diet and Health. Implications for Reducing Chronic Disease Risk. Washington, DC: National Academy Press; 1989.
34 Forster J L, Jeffery R W, Schmid T L, Kramer F M. Preventing weight gain in adults: a pound of prevention. Health Psychol. 1988;7:515-525. [pmid: 3215160].
35 Lenfant C. NHLBI Clinical Guidelines: another look. Circulation. 1995;91:617-618. [pmid: 7828283].
36 Dickersin K, Min Y I, Meinert C L. Factors influencing publication of research results. Follow-up of applications submitted to two institutional review boards. JAMA. 1992;267:374-378. [pmid: 1727960].
37 Dickersin K. The existence of publication bias and risk factors for its occurrence. JAMA. 1990;263:1385-1389. [pmid: 2406472].
38 Dickersin K, Min Y I. Publication bias: the problem that won't go away. Ann N Y Acad Sci. 1993;703:135-146. [pmid: 8192291].
39 Allison D B, Faith M S, Gorman B S. Publication bias in obesity treatment trials?. Int J Obes Relat Metab Disord. 1996;20:931-937. [pmid: 8910098].
40 Bray GA. Obesity in Perspective: a Conference. John E. Fogarty International Center for Advanced Study in the Health Sciences. Washington, DC: Govt Print Office; 1975. DHEW publication no. (NIH) 75–708.
41 Bray G A. Obesity in America. An overview of the Second Fogarty International Center conference on obesity. Int J Obes. 1979;3:363-375. [pmid: 43296].
42 Health implications of obesity. National Institutes of Health Consensus Development Conference Statement. Ann Intern Med. 1985;103:1073-1077. [pmid: 4062128].
43 U.S. Department of Health and Human Services. Healthy People 2000: National health promotion and disease prevention objectives: Washington, DC: Public Health Service; 1991. DHHS publication no. (PHS) 91–50213.
44 Thomas PR, ed. Weighing the Options. Criteria for Evaluating Weight-Management Programs. Washington, DC: National Academy Press; 1995.
45 Najjar M F, Rowland M. Anthropometric reference data and prevalence of overweight, United States, 1976-80. Vital Health Stat [11]. 1987;238:1-73. [pmid: 3424692].
46 Wolf A M, Colditz G A. Social and economic effects of body weight in the United States. Am J Clin Nutr. 1996;63:466S-469S. [pmid: 8615344].
47 Flynn M A, Nolph G B, Baker A S, Krause G. Aging in humans: a continuous 20-year study of physiologic and dietary parameters. J Am Coll Nutr. 1992;11:660-672. [pmid: 1460180].
48 Flegal K M, Carroll M D, Kuczmarski R J, Johnson C L. Overweight and obesity in the United States: prevalence and trends, 1960-1994. Int J Obes Relat Metab Disord. 1998;22:39-47. [pmid: 9481598].
49 Centers for Disease Control. Prevalence of overweight among adolescents—United States, 1988-91. MMWR Morb Mortal Wkly Rep. 1994;43:818-821. [pmid: 7968998].
50 McGarvey S T. Obesity in Samoans and a perspective on its etiology in Polynesians. Am J Clin Nutr. 1991;53:1586S-1594S. [pmid: 2031491].
51 Klatsky A L, Armstrong M A. Cardiovascular risk factors among Asian Americans living in northern California. Am J Public Health. 1991;81:1423-1428. [pmid: 1951798].
52 Welty T K, Lee E T, Yeh J, et al. Cardiovascular disease risk factors among American Indians. The Strong Heart Study. Am J Epidemiol. 1995;142:269-287. [pmid: 7631631].
53 Leigh J P, Fries J F, Hubert H B. Gender and race differences in the correlation between body mass and education in the 1971-1975 NHANES I. J Epidemiol Community Health. 1992;46:191-196. [pmid: 1645069].
54 Kuczmarski R J. Prevalence of overweight and weight gain in the United States. Am J Clin Nutr. 1992;55:495S-502S. [pmid: 1733118].
55 Kuczmarski R J, Flegal K M, Campbell S M, Johnson C L. Increasing prevalence of overweight among US adults. The National Health and Nutrition Examination Surveys, 1960 to 1991. JAMA. 1994;272:205-211. [pmid: 8022039].
56 Pi-Sunyer F X. Medical hazards of obesity. Ann Intern Med. 1993;119:655-660. [pmid: 8363192].
57 Seidell J C. The impact of obesity on health status: some implications for health care costs. Int J Obes Relat Metab Disord. 1995;19(Suppl 6):S13-S16. [pmid: 8581114].
58 Wolf A M, Colditz G A. Current estimates of the economic costs of obesity in the United States. Obes Res. 1998;6:97-106. [pmid: 9545015].
59 Wolf A M, Colditz G A. The cost of obesity: the U.S. perspective. Pharmacoeconomics. 1994;5:34-37. [pmid: 10147247].
60 Colditz G A. Economic costs of obesity. Am J Clin Nutr. 1992;55:503S-507S. [pmid: 1733119].
61 Levy E, Levy P, Le Pen C, Basdevant A. The economic cost of obesity: the French situation. Int J Obes Relat Metab Disord. 1995;19:788-792. [pmid: 8589779].
62 Segal L, Carter R, Zimmet P. The cost of obesity - the Australian perspective. Pharmacoeconomics. 1994;5:45-52. [pmid: 10147249].
63 Seidell J C. Obesity in Europe. Obes Res. 1995;3:89S-93S. [pmid: 8581793].
64 National Task Force on Prevention and Treatment of Obesity. Towards Prevention of Obesity: Research Directions. Obes Res. 1994;2:571-584. [pmid: 16355518].
65 World Health Organization. Obesity: Preventing and Managing the Global Epidemic. Report of a WHO Consultation of Obesity. Geneva, 3–5 June 1997.
66 Winkleby M A, Feldman H A, Murray D M. Joint analysis of three U.S. community intervention trials for reduction of cardiovascular disease risk. J Clin Epidemiol. 1997;50:645-658. [pmid: 9250263].
67 Carleton R A, Lasater T M, Assaf A R, Feldman H A, McKinlay S. The Pawtucket Heart Health Program: community changes in cardiovascular risk factors and projected disease risk. Am J Public Health. 1995;85:777-785. [pmid: 7762709].
68 Davis SM. Cardiovascular Health Promotion Project. American Indian Program Recaptures Past to Improve Children's Future (Pathways). Heartmemo (Special Edition). 1996:25–27.
69 Epstein L H, Valoski A, Wing R R, McCurley J. Ten-year followup of behavioral, family-based treatment for obese children. JAMA. 1990;264:2519-2523. [pmid: 2232019].
70 Pan X R, Li G W, Hu Y H, et al. Effects of diet and exercise in preventing NIDDM in people with impaired glucose tolerance. The Da Qing IGT and Diabetes Study. Diabetes Care. 1997;20:537-544. [pmid: 9096977].
71 James W P. A public health approach to the problem of obesity. Int J Obes Relat Metab Disord. 1995;19(Suppl 3):S37-S45. [pmid: 8581075].
72 Jeffery R W. Population perspectives on the prevention and treatment of obesity in minority populations. Am J Clin Nutr. 1991;53(6 Suppl):1621S-1624S. [pmid: 2031496].
73 Lewin-Epstein N. Determinants of regular source of health care in Black, Mexican, Puerto Rican, and non-Hispanic White population. Med Care. 1991;29:543-557. [pmid: 2046408].
74 O'Hare WP. America's Minorities—The demographics of diversity. Population Bulletin. Washington, DC: Population Reference Bureau, Inc.; 1992:47:4.
75 Link B G, Phelan J C. Understanding sociodemographic differences in health—the role of fundamental social causes. Am J Public Health. 1996;86:471-473. [pmid: 8604773].
76 Ballantyne D, Devine B L, Fife R. Interrelation of age, obesity, cigarette smoking, and blood pressure in hypertensive patients. BMJ. 1978;1:880-881. [pmid: 638505].
77 Brennan P J, Simpson J M, Blacket R B, McGilchrist C A. The effects of body weight on serum cholesterol, serum triglycerides, serum urate, and systolic blood pressure. Aust N Z J Med. 1980;10:15-20. [pmid: 6929670].
78 Havlik R J, Hubert H B, Fabsitz R R, Feinleib M. Weight and hypertension. Ann Intern Med. 1983;98:855-859. [pmid: 6847025].
79 Loggie J M, Horan M J, Hohn A R, Gruskin A B, Dunbar J B, Havlik R J. Juvenile hypertension: highlights of a workshop. J Pediatr. 1984;104:657-663. [pmid: 6716214].
80 MacMahon S W, Blacket R B, Macdonald G J, Hall W. Obesity, alcohol consumption and blood pressure in Australian men and women. The National Heart Foundation of Australia Risk Factor Prevalence Study. J Hypertens. 1984;2:85-91. [pmid: 6530540].
81 Colditz G A, Willett W C, Stampfer M J, et al. Weight as a risk factor for clinical diabetes in women. Am J Epidemiol. 1990;132:501-513. [pmid: 2389754].
82 Chan J M, Rimm E B, Colditz G A, Stampfer M J, Willett W C. Obesity, fat distribution, and weight gain as risk factors for clinical diabetes in men. Diabetes Care. 1994;17:961-969. [pmid: 7988316].
83 Colditz G A, Willett W C, Rotnitzky A, Manson J E. Weight gain as a risk factor for clinical diabetes mellitus in women. Ann Intern Med. 1995;122:481-486. [pmid: 7872581].
84 Ford E S, Williamson D F, Liu S. Weight change and diabetes incidence: findings from a national cohort of US adults. Am J Epidemiol. 1997;146:214-222. [pmid: 9247005].
85 Despres J P, Nadeau A, Tremblay A, et al. Role of deep abdominal fat in the association between regional adipose tissue distribution and glucose tolerance in obese women. Diabetes. 1989;38:304-309. [pmid: 2645187].
86 Haffner S M, Mitchell B D, Hazuda H P, Stern M P. Greater influence of central distribution of adipose tissue on incidence of non-insulin-dependent diabetes in women than men. Am J Clin Nutr. 1991;53:1312-1317. [pmid: 2021139].
87 Sparrow D, Borkan G A, Gerzof S G, Wisniewski C, Silbert C K. Relationship of fat distribution to glucose tolerance. Results of computed tomography in male participants of the Normative Aging Study. Diabetes. 1986;35:411-415. [pmid: 3956878].
88 Lundgren H, Bengtsson C, Blohme G, Lapidus L, Sjostrom L. Adiposity and adipose tissue distribution in relation to incidence of diabetes in women: results from a prospective population study in Gothenburg, Sweden. Int J Obes. 1989;13:413-423. [pmid: 2793297].
89 Ohlson L O, Larsson B, Svardsudd K, et al. The influence of body fat distribution on the incidence of diabetes mellitus. 13.5 years of follow-up of the participants in the study of men born in 1913. Diabetes. 1985;34:1055-1058. [pmid: 4043554].
90 Willett W C, Manson J E, Stampfer M J, et al. Weight, weight change, and coronary heart disease in women. Risk within the ‘normal’ weight range. JAMA. 1995;273:461-465. [pmid: 7654270].
91 Carman W J, Sowers M, Hawthorne V M, Weissfeld L A. Obesity as a risk factor for osteoarthritis of the hand and wrist: a prospective study. Am J Epidemiol. 1994;139:119-129. [pmid: 8296779].
92 Felson D T, Anderson J J, Naimark A, Walker A M, Meenan R F. Obesity and knee osteoarthritis. The Framingham Study. Ann Intern Med. 1988;109:18-24. [pmid: 3377350].
93 Felson D T, Zhang Y, Anthony J M, Naimark A, Anderson J J. Weight loss reduces the risk for symptomatic knee osteoarthritis in women. The Framingham Study. Ann Intern Med. 1992;116:535-539. [pmid: 1543306].
94 Felson D T. Weight and osteoarthritis. J Rheumatol Suppl. 1995;43:7-9. [pmid: 7752143].
95 McGoey B V, Deitel M, Saplys R J, Kliman M E. Effect of weight loss on musculoskeletal pain in the morbidly obese. J Bone Joint Surg [Br]. 1990;72-B:322-323. [pmid: 2138158].
96 Chua W Chediak A D Obstructive sleep apnea. Treatment improves quality of life—and may prevent death Postgrad Med 1994 95 123–126, 131, 135–138. 8309856
97 Loube D I, Loube A A, Mitler M M. Weight loss for obstructive sleep apnea: the optimal therapy for obese patients. J Am Diet Assoc. 1994;94:1291-1295. [pmid: 7963174].
98 Davies R J, Stradling J R. The relationship between neck circumference, radiographic pharyngeal anatomy, and the obstructive sleep apnoea syndrome. Eur Respir J. 1990;3:509-514. [pmid: 2376247].
99 Giovannucci E, Ascherio A, Rimm E B, Colditz G A, Stampfer M J, Willett W C. Physical activity, obesity, and risk for colon cancer and adenoma in men. Ann Intern Med. 1995;122:327-334. [pmid: 7847643].
100 Graham S, Marshall J, Haughey B, et al. Dietary epidemiology of cancer of the colon in western New York. Am J Epidemiol. 1988;128:490-503. [pmid: 2843038].
101 Klatsky A L, Armstrong M A, Friedman G D, Hiatt R A. The relations of alcoholic beverage use to colon and rectal cancer. Am J Epidemiol. 1988;128:1007-1015. [pmid: 3189277].
102 Lee I M, Paffenbarger R S Jr. Quetelet's index and risk of colon cancer in college alumni. J Natl Cancer Inst. 1992;84:1326-1331. [pmid: 1495102].
103 Le Marchand L, Wilkens L R, Mi M P. Obesity in youth and middle age and risk of colorectal cancer in men. Cancer Causes Control. 1992;3:349-354. [pmid: 1617122].
104 Martinez ME, Giovannucci E, Spiegelman D, et al. Physical activity, body size, and colorectal cancer in women. Am J Epidemiol. 1996:146-S73.
105 Must A, Jacques P F, Dallal G E, Bajema C J, Dietz W H. Long-term morbidity and mortality of overweight adolescents. A follow-up of the Harvard Growth Study of 1922 to 1935. N Engl J Med. 1992;327:1350-1355. [pmid: 1406836].
106 Phillips R L, Snowdon D A. Dietary relationships with fatal colorectal cancer among Seventh-Day Adventists. J Natl Cancer Inst. 1985;74:307-317. [pmid: 3856044].
107 Giovannucci E, Colditz G A, Stampfer M J, Willett W C. Physical activity, obesity, and risk of colorectal adenoma in women (United States). Cancer Causes Control. 1996;7:253-263. [pmid: 8740738].
108 Giovannucci E. Insulin and colon cancer. Cancer Causes Control. 1995;6:164-179. [pmid: 7749056].
109 Chu S Y, Lee N C, Wingo P A, Senie R T, Greenberg R S, Peterson H B. The relationship between body mass and breast cancer among women enrolled in the Cancer and Steroid Hormone Study. J Clin Epidemiol. 1991;44:1197-1206. [pmid: 1941014].
110 Helmrich S P, Shapiro S, Rosenberg L, et al. Risk factors for breast cancer. Am J Epidemiol. 1983;117:35-45. [pmid: 6823951].
111 Rosenberg L, Palmer J R, Miller D R, Clarke E A, Shapiro S. A case-control study of alcoholic beverage consumption and breast cancer. Am J Epidemiol. 1990;131:6-14. [pmid: 2293754].
112 Willett W C, Browne M L, Bain C, et al. Relative weight and risk of breast cancer among premenopausal women. Am J Epidemiol. 1985;122:731-740. [pmid: 4050766].
113 Hunter D J, Willett W C. Diet, body size, and breast cancer. Epidemiol Rev. 1993;15:110-132. [pmid: 8405195].
114 Huang Z, Hankinson S E, Colditz G A, et al. Dual effects of weight and weight gain on breast cancer risk. JAMA. 1997;278:1407-1411. [pmid: 9355998].
115 Schottenfeld D, Fraumeni JF. Cancer Epidemiology and Prevention. New York: Oxford University Press, 1996.
116 Hartz A J, Barboriak P N, Wong A, Katayaa K P, Rimm A A. The association of obesity with infertility and related menstrual abnormalities in women. Int J Obes. 1979;3:57-73. [pmid: 528119].
117 Rich-Edwards J W, Goldman M B, Willett W C, et al. Adolescent body mass index and infertility caused by ovulatory disorder. Am J Obstet Gynecol. 1994;171:171-177. [pmid: 8030695].
118 Dunaif A. Polycystic Ovary Syndrome. Boston: Blackwell Scientific Publications; 1992.
Garbaciak J A Jr, Richter M, Miller S, Barton J J. Maternal weight and pregnancy complications. Am J Obstet Gynecol. 1985;152:238-245. [pmid: 4003470].
120 Keppel K G, Taffel S M. Pregnancy-related weight gain and retention: implications of the 1990 Institute of Medicine guidelines. Am J Public Health. 1993;83:1100-1103. [pmid: 8342716].
121 Smith D E, Lewis C E, Caveny J L, Perkins L L, Burke G L, Bild D E. Longitudinal changes in adiposity associated with pregnancy. The CARDIA Study. Coronary Artery Risk Development in Young Adults Study. JAMA. 1994;271:1747-1751. [pmid: 8196117].
122 Johnson S R, Kolberg B H, Varner M W, Railsback L D. Maternal obesity and pregnancy. Surg Gynecol Obstet. 1987;164:431-437. [pmid: 3576419].
123 Prentice A, Goldberg G. Maternal obesity increases congenital malformations. Nutr Rev. 1996;54:146-152. [pmid: 8783881].
124 Stunkard AJ, Wadden TA. Psychological aspects of human obesity. In: Bjorntorp P, Brodoff BN, eds. Obesity. Philadelphia: Lippincott; 1992:352–360.
125 Brownell KD, Fairburn C. Psychosocial consequences of obesity. In: Stunkard AJ, Sobal JG, eds. Eating Disorders and Obesity: A Comprehensive Handbook. New York: Guilford Press; 1995:417–421.
126 Wadden TA, Stunkard AJ. Psychosocial consequences of obesity and dieting-research and clinical findings. In: Stunkard AJ, Wadden TA, eds. Obesity Theory and Therapy. New York: Raven Press; 1993:163–177.
127 Faith MS, Allison DB. Assessment of psychological status among obese persons. In: Thompson JK, ed. Body Image, Eating Disorders, and Obesity: An Integrative Guide For Assessment and Treatment. Washington, DC: American Psychological Association; 1996:365–387.
128 Allon N. The stigma of overweight in everyday life. In: Wolman BB, DeBerry S, eds. Psychological Aspects of Obesity: A Handbook. New York: Van Nostrand Reinhold; 1982:130–174.
129 Feinleib M. Epidemiology of obesity in relation to health hazards. Ann Intern Med. 1985;103:1019-1024. [pmid: 4062117].
130 Garrison R J, Castelli W P. Weight and 30-year mortality of men in the Framingham Study. Ann Intern Med. 1985;103:1006-1009. [pmid: 4062116].
131 Rabkin S W, Mathewson F A, Hsu P H. Relation of body weight to development of ischemic heart disease in a cohort of young North American men after a 26 year observation period: the Manitoba Study. Am J Cardiol. 1977;39:452-458. [pmid: 842466].
132 Cutler JA, Psaty BM, MacMahon S, Furberg CD. Public health issues in hypertension control: what has been learned from clinical trials. In: Laragh JH, Brenner BM, eds. Hypertension: Pathophysiology, Diagnosis, and Management. New York: Raven Press; 1995:253–270.
133 Denke M A, Sempos C T, Grundy S M. Excess body weight. An underrecognized contributor to high blood cholesterol levels in white American men. Arch Intern Med. 1993;153:1093-1103. [pmid: 8481076].
134 Denke M A, Sempos C T, Grundy S M. Excess body weight. An underrecognized contributor to dyslipidemia in white American women. Arch Intern Med. 1994;154:401-410. [pmid: 8117172].
135 Ashley F W Jr, Kannel W B. Relation of weight change to changes in atherogenic traits: the Framingham Study. J Chronic Dis. 1974;27:103-114. [pmid: 4830839].
136 Hershcopf R J, Elahi D, Andres R, et al. Longitudinal changes in serum cholesterol in man: an epidemiologic search for an etiology. J Chronic Dis. 1982;35:101-114. [pmid: 7056835].
137 Shekelle R B, Shryock A M, Paul O, et al. Diet, serum cholesterol, and death from coronary heart disease. The Western Electric study. N Engl J Med. 1981;304:65-70. [pmid: 7442730].
138 Manson J E, Colditz G A, Stampfer M J, et al. A prospective study of obesity and risk of coronary heart disease in women. N Engl J Med. 1990;322:882-889. [pmid: 2314422].
139 Reeder B A, Angel A, Ledoux M, Rabkin S W, Young T K, Sweet L E. Obesity and its relation to cardiovascular disease risk factors in Canadian adults. Canadian Heart Health Surveys Research Group. CMAJ. 1992;146:2009-2019. [pmid: 1596850].
140 Carlson L A, Lindstedt S. The Stockholm prospective study. 1. The initial values for plasma lipids. Acta Med Scand Suppl. 1968;493:1-135. [pmid: 5257749].
141 Mann J I, Lewis B, Shepherd J, et al. Blood lipid concentrations and other cardiovascular risk factors: distribution, prevalence, and detection in Britain. BMJ. 1988;296:1702-1706. [pmid: 3135884].
142 National Cholesterol Education Program. Second Report of the Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel II). Circulation. 1994;89:1333-1445. [pmid: 8124825].
143 Glueck C J, Taylor H L, Jacobs D, Morrison J A, Beaglehole R, Williams O D. Plasma high-density lipoprotein cholesterol: association with measurements of body mass. The Lipid Research Clinics Program Prevalence Study. Circulation. 1980;62(IV):62-69. [pmid: 7418145].
144 Garrison R J, Wilson P W, Castelli W P, Feinleib M, Kannel W B, McNamara P M. Obesity and lipoprotein cholesterol in the Framingham offspring study. Metabolism. 1980;29:1053-1060. [pmid: 7432169].
145 Anderson K M, Wilson P W F, Garrison R J, Castelli W P. Longitudinal and secular trends in lipoprotein cholesterol measurements in a general population sample: The Framingham offspring study. Atherosclerosis. 1987;68:59-66. [pmid: 3500729].
146 Law M R, Wald N J, Thompson S G. By how much and how quickly does reduction in serum cholesterol concentration lower risk of ischaemic heart disease?. BMJ. 1994;308:367-773. [pmid: 8043072].
147 Rydker P M, Hennekens C H, Stampfer M J. A prospective study of lipoprotein (a) and the risk for myocardial infarction. JAMA. 1993;270:2195-2199. [pmid: 8411602].
148 Miller B D, Alderman E L, Haskell W L, Fair J M, Krauss R M. Predominance of dense low-density lipoprotein particles predicts angiograpic benefit of therapy in the Stanford coronary risk intervention study. Circulation. 1996;94:2146-2153. [pmid: 8901665].
149 Lamarche B, Tchernof A, Moorjani S, et al. Small, dense low-density lipoprotein particles as a predictor of the risk of ischemic heart disease in men. Prospective results from the Quebec Cardiovascular Study. Circulation. 1997;95:69-75. [pmid: 8994419].
150 Reaven G M, Chen Y D, Jeppesen J, Maheux P, Krauss R M. Insulin resistance and hyperinsulinemia in individuals with small, dense low density lipoprotein particles. J Clin Invest. 1993;92:141-146. [pmid: 8325978].
151 Selby J V, Austin M A, Newman B, et al. LDL subclass phenotypes and the insulin resistance syndrome in women. Circulation. 1993;88:381-387. [pmid: 8339401].
152 Tchernof A, Lamarche B, Prud'Homme D, et al. The dense LDL phenotype: association with plasma lipoprotein levels, visceral obesity, and hyperinsulinemia in men. Diabetes Care. 1996;19:629-637. [pmid: 8725863].
153 Knowler W C, Pettitt D J, Savage P J, Bennett P H. Diabetes incidence in Pima Indians: contributions of obesity and parental diabetes. Am J Epidemiol. 1981;113:144-156. [pmid: 7468572].
154 Lee E T, Howard B V, Savage P J, et al. Diabetes and impaired glucose tolerance in three American Indian populations aged 45–74 years. The Strong Heart Study. Diabetes Care. 1995;18:599-610. [pmid: 8585996].
155 Higgins M, Kannel W, Garrison R, Pinsky J, Stokes J. Hazards of obesity—the Framingham experience. Acta Med Scand Suppl. 1988;723:23-36. [pmid: 3164971].
156 Donahue R P, Abbott R D. Central obesity and coronary heart disease in men. Lancet. 1987;2:1215. [pmid: 2890843].
157 Ducimetiere P, Richard J L. The relationship between subsets of anthropometric upper versus lower body measurements and coronary heart disease risk in middle-aged men. The Paris Prospective Study I. Int J Obes. 1989;13:111-121. [pmid: 2703290].
158 Lapidus L, Bengtsson C, Larsson B, Pennert K, Rybo E, Sjostrom L. Distribution of adipose tissue and risk of cardiovascular disease and death: a 12 year follow up of participants in the population study of women in Gothenburg, Sweden. BMJ. 1984;289:1257-1261. [pmid: 6437507].
159 Larsson B, Svardsudd K, Welin L, Wilhelmsen L, Bjorntorp P, Tibblin G. Abdominal adipose tissue distribution, obesity, and risk of cardiovascular disease and death: 13 year follow up of participants in the study of men born in 1913. BMJ. 1984;288:1401-1404. [pmid: 6426576].
160 Bjorntorp P. The associations between obesity, adipose tissue distribution, and disease. Acta Med Scand Suppl. 1988;723:121-134. [pmid: 3293356].
161 Fujioka S, Matsuzawa Y, Tokunaga K, Tarui S. Contribution of intra-abdominal fat accumulation to the impairment of glucose and lipid metabolism in human obesity. Metabolism. 1987;36:54-59. [pmid: 3796297].
162 Shaper A G, Wannamethee S G, Walker M. Body weight: implications for the prevention of coronary heart disease, stroke, and diabetes mellitus in a cohort study of middle aged men. BMJ. 1997;314:1311-1317. [pmid: 9158466].
163 Tokunaga K, Matsuzawa Y, Kotani K, et al. Ideal body weight estimated from the body mass index with the lowest morbidity. Int J Obes. 1991;15:1-5. [pmid: 2010254].
164 Jousilahti P, Tuomilehto J, Vartiainen E, Pekkanen J, Puska P. Body weight, cardiovascular risk factors, and coronary mortality. 15-year follow-up of middle-aged men and women in eastern Finland. Circulation. 1996;93:1372-1379. [pmid: 8641026].
165 DiBianco R. The changing syndrome of heart failure: an annotated review as we approach the 21st century. J Hypertens Suppl. 1994;12:S73-S87. [pmid: 7965278].
166 Kannel W B, Cupples A. Epidemiology and risk profile of cardiac failure. Cardiovasc Drugs Ther. 1988;2(Suppl 1):387-395. [pmid: 3154646].
167 Savage M P, Krolewski A S, Kenien G G, Lebeis M P, Christlieb A R, Lewis S M. Acute myocardial infarction in diabetes mellitus and significance of congestive heart failure as a prognostic factor. Am J Cardiol. 1988;62:665-669. [pmid: 3421162].
168 Eriksson H, Svardsudd K, Larsson B, et al. Risk factors for heart failure in the general population: the study of men born in 1913. Eur Heart J. 1989;10:647-656. [pmid: 2788575].
169 Eriksson H, Wilhelmsen L, Caidahl K, Svardsudd K. Epidemiology and prognosis of heart failure. Z Kardiol. 1991;80(Suppl 8):1-6. [pmid: 1796625].
170 Shimizu M, Isogai Y. Heart failure due to metabolic heart disorders. Nippon Rinsho. 1993;51:1362-1366. [pmid: 8331805].
171 Urbina E M, Gidding S S, Bao W, Pickoff A S, Berdusis K, Berenson G S. Effect of body size, ponderosity, and blood pressure on left ventricular growth in children and young adults in the Bogalusa Heart Study. Circulation. 1995;91:2400-2406. [pmid: 7729027].
172 Alpert M A, Hashimi M W. Obesity and the heart. Am J Med Sci. 1993;306:117-123. [pmid: 8362892].
173 Garavaglia G E, Messerli F H, Nunez B D, Schmieder R E, Grossman E. Myocardial contractility and left ventricular function in obese patients with essential hypertension. Am J Cardiol. 1988;62:594-597. [pmid: 3414551].
174 Ritter M M, Schraudolph M, Richter W O, Herbert M, Wiebecke B, Schwandt P. Obesity, heart failure and pulmonary insufficiency in a 26-year-old female. Med Klin. 1990;85:371-375. [pmid: 2377148].
175 Huang C, Ross P D, Lydick E, Wasnich R D. Factors associated with joint pain among postmenopausal women. Int J Obes Relat Metab Disord. 1997;21:349-354. [pmid: 9152735].
176 Williams R A, Foulsham B M. Weight reduction in osteoarthritis using phentermine. Practitioner. 1981;225:231-232. [pmid: 7022428].
177 Garfinkel L. Overweight and mortality. Cancer. 1986;58:1826-1829. [pmid: 3756807].
178 Williamson D F, Madans J, Pamuk E, Flegal K M, Kendrick J S, Serdula M K. A prospective study of childbearing and 10-year weight gain in US white women 25 to 45 years of age. Int J Obes Relat Metab Disord. 1994;18:561-569. [pmid: 7951478].
179 Cnattingius S, Bergstrom R, Lipworth L, Kramer M S. Prepregnancy weight and the risk of adverse pregnancy outcomes. N Engl J Med. 1998;338:147-152. [pmid: 9428815].
180 Shils ME, Olson JA, Shike M, eds. Modern Nutrition in Health and Disease. Philadelphia: Lea & Febiger; 1994.
181 Cogswell M E, Serdula M K, Hungerford D W, Yip R. Gestational weight gain among average-weight and overweight women—what is excessive?. Am J Obstet Gynecol. 1995;172:705-712. [pmid: 7856711].
182 Institute of Medicine. Committee on Nutritional Status During Pregnancy and Lactation. Nutrition During Pregnancy: Part I, Weight Gain: Part II, Nutrient Supplements. Washington, DC: National Academy Press, 1990.
183 O'Neil PM, Jarrell MP. Psychological aspects of obesity and dieting. In: Wadden TA, Van Itallie TB, eds. Treatment Of The Seriously Obese Patient. New York: Guilford Press; 1992:252-270.
184 Jarvie G J, Lahey B B, Graziano W, Framer E. Childhood obesity and social stigma: what we know and what we don't know. Dev Rev. 1983;3:237-273.
185 DeJong W, Kleck RE. The Social Psychological Effects of Overweight. In: Herman CP, Zanna MP, Higgins ET, eds. Physical Appearance, Stigma, and Social Behavior. Hillsdale, NJ: L. Erlbaum; 1986:65–88.
186 Goodman N, Dornbusch S M, Richardson S A, Hastof A H. Variant reactions to physical disabilities. Amer Sociolo Rev. 1963;28:429-435.
187 Lerner R M, Gellert E. Body build identification, preference, and aversion in children. Dev Psychol. 1969;5:456-462.
188 Richardson S A, Hastorf A H, Goodman N, Dornbusch S M. Cultural uniformity in reaction to physical disabilities. Am Soc Rev. 1961;26:241-247.
189 Staffieri J R. Body build and behavioral expectancies in young females. Dev Psychol. 1972;6:125-127.
190 Staffieri J R. A study of social stereotype of body image in children. J Pers Soc Psychol. 1967;7:101-104. [pmid: 6052651].
191 Lerner R M, Korn S J. The development of body build stereotypes in males. Child Dev. 1972;43:908-920. [pmid: 5056613].
192 Blumberg P, Mellis L P. Medical students' attitudes toward the obese and the morbidly obese. Int J Eat Disord. 1985;4:169-175.
193 Maddox G L, Liederman V. Overweight as a social disability with medical implications. J Med Educ. 1969;44:214-220. [pmid: 5774591].
194 Rand C S, Macgregor A M. Morbidly obese patients' perceptions of social discrimination before and after surgery for obesity. South Med J. 1990;83:1390-1395. [pmid: 2251527].
195 Crandall C S, Biernat M. The ideology of anti-fat attitudes. J Appl Soc Psychol. 1990;20:227-243.
196 Maddox G L, Back K W, Liederman W R. Overweight as social deviance and disability. J Health Soc Behav. 1968;9:287-298. [pmid: 5706544].
197 Larkin J C, Pines H A. No fat persons need apply: experimental studies of the overweight stereotype and hiring preference. Sociology of Work and Occupations. 1979;6:312-327.
198 Pingitore R, Dugoni B L, Tindale R S, Spring B. Bias against overweight job applicants in a simulated employment interview. J Appl Psychol. 1994;79:909-917. [pmid: 7852208].
199 Roe D A Eickwort K R Relationships between obesity and associated health factors with unemployment among low income women J Am Med Womens Assoc 1976 31 193–194, 198–199, 203–204. 180078
200 Canning H, Mayer J. Obesity: its possible effect on college acceptance. N Eng J Med. 1966;275:1172-1174.
201 Crandall C S. Do heavy-weight students have more difficulty paying for college?. Personality Soc Psychol Bull. 1991;17:606-611.
202 Sargent J D, Blanchflower D G. Obesity and stature in adolescence and earnings in young adulthood. Analysis of a British birth cohort. Arch Pediatr Adolesc Med. 1994;148:681-687. [pmid: 8019620].
203 Karris L. Prejudice against obese renters. J Soc Psych. 1977;101:159-160.
204 Gortmaker S L, Must A, Perrin J M, Sobol A M, Dietz W H. Social and economic consequences of overweight in adolescence and young adulthood. N Engl J Med. 1993;329:1008-1012. [pmid: 8366901].
205 Massara E B, Stunkard A J. A method of quantifying cultural ideals of beauty and the obese. Int J Obes. 1979;3:149-152. [pmid: 528126].
206 Crandall C S, Martinez R. Culture, ideology, and antifat attitudes. Personality Soc Psychol Bull. 1996;22:1165-1176.
207 Striegel-Moore R, Rodin J. The influences of psychological variables in obesity. In: Brownell KD, Foreyt JP, eds. Handbook of Eating Disorders: Physiology, Psychology, and Treatment of Obesity, Anorexia, and Bulimia. New York: Basic Books; 1986:99–121.
208 Wadden T A, Stunkard A J. Psychopathology and obesity. Ann N Y Acad Sci. 1987;499:55-65. [pmid: 3300493].
209 Lapidus L, Bengtsson C, Hallstrom T, Bjorntorp P. Obesity, adipose tissue distribution and health in women—results from a population study in Gothenburg, Sweden. Appetite. 1989;12:25-35. [pmid: 2789494].
210 Lissau I, Sorensen T I. Parental neglect during childhood and increased risk of obesity in young adulthood. Lancet. 1994;343:324-327. [pmid: 7905145].
211 Sullivan M, Karlsson J, Sjostrom L, et al. Swedish obese subjects (SOS)—an intervention study of obesity. Baseline evaluation of health and psychosocial functioning in the first 1743 subjects examined. Int J Obes Relat Metab Disord. 1993;17:503-512. [pmid: 8220652].
212 Friedman M A, Brownell K D. Psychological correlates of obesity: moving to the next research generation. Psychol Bull. 1995;117:3-20. [pmid: 7870862].
213 Stunkard A J, Rush J. Dieting and depression reexamined. A critical review of reports of untoward responses during weight reduction for obesity. Ann Intern Med. 1974;81:526-533. [pmid: 4606433].
214 Prather R C, Williamson D A. Psychopathology associated with bulimia, binge eating, and obesity. Int J Eat Disord. 1988;7:177-184.
215 Fitzgibbon M L, Stolley M R, Kirschenbaum D S. Obese people who seek treatment have different characteristics than those who do not seek treatment. Health Psychol. 1993;12:342-345. [pmid: 8223357].
216 Gormally J, Black S, Daston S, Rardin D. The assessment of binge eating severity among obese persons. Addict Behav. 1982;7:47-55. [pmid: 7080884].
217 Loro A D Jr, Orleans C S. Binge eating in obesity: preliminary findings and guidelines for behavioral analysis and treatment. Addict Behav. 1981;6:155-166. [pmid: 6943912].
218 Marcus M D, Wing R R, Fairburn C G. Cognitive treatment of binge eating versus behavioral weight control in the treatment of binge eating disorder. Annals of Behavioral Medicine. 1995;17:S090.
219 Spitzer R L, Devlin M, Walsh B T, et al. Binge eating disorder: a multisite field trial of the diagnostic criteria. Int J Eat Disord. 1992;11:191-203.
220 Yanovski S Z, Gormally J F, Leser M S, Gwirtsman H E, Yanovski J A. Binge eating disorder affects outcome of comprehensive very-low-calorie diet treatment. Obes Res. 1994;2:205-212. [pmid: 16353422].
221 Spitzer R L, Yanovski S, Wadden T, et al. Binge eating disorder: its further validation in a multisite study. Int J Eat Disord. 1993;13:137-153. [pmid: 8477283].
222 Wilfley D E, Agras W S, Telch C F, et al. Group cognitive-behavioral therapy and group interpersonal psychotherapy for the nonpurging bulimic individual: a controlled comparison. J Consult Clin Psychol. 1993;61:296-305. [pmid: 8473584].
223 Wilfley D E, Cohen L R. Psychological treatment of bulimia nervosa and binge eating disorder. Psychopharmacol Bull. 1997;33:437-453. [pmid: 9550890].
224 Yanovski S Z. Binge eating disorder: Current knowledge and future directions. Obes Res. 1993;1:306-324. [pmid: 16350580].
225 Yanovski S Z, Nelson J E, Dubbert B K, Spitzer R L. Association of binge eating disorder and psychiatric comorbidity in obese subjects. Am J Psychiatry. 1993;150:1472-1479. [pmid: 8379549].
226 Wilfley D E, Pike K M, Striegel-Moore R. Toward an integrated model of risk for binge eating disorder. J Gender Cult Health. 1997;2:1-32.
227 Fairburn CG, Wilson GT. Binge Eating: Nature, Assessment, and Treatment. New York: Guilford Press; 1993.
228 Castonguay L G, Eldredge K L, Agras W S. Binge eating disorder: current state and future directions. Clini Psychol Rev. 1995;15:865-890.
229 Striegel-Moore R H, Wilson G T, Wilfley D E, Elder K A, Brownell K D. Binge eating in an obese community sample. Int J Eat Disord. 1998;23:27-37. [pmid: 9429916].
230 Telch C F, Agras W S, Rossiter E M. Binge eating increases with increasing adiposity. Int J Eat Disord. 1988;7:115-119.
231 Kenardy J, Arnow B, Agras W S. The aversiveness of specific emotional states associated with binge-eating in obese subjects. Aust N Z J Psychiatry. 1996;30:839-844. [pmid: 9034475].
232 Marcus M D, Wing R R, Ewing L, Kern E, Gooding W, McDermott M. Psychiatric disorders among obese binge eaters. Int J Eat Disord. 1990;9:69-77.
233 Marcus M D, Wing R R, Hopkins J. Obese binge eaters: affect, cognitions, and response to behavioral weight control. J Consult Clin Psychol. 1988;56:433-439. [pmid: 3397436].
234 Molinari E, Ragazzoni P, Morosin A. Psychopathology in obese subjects with and without binge-eating disorder and in bulimic subjects. Psychol Rep. 1997;80:1327-1335. [pmid: 9246897].
235 Mussell M P, Mitchell J E, de Zwaan M, Crosby R D, Seim H C, Crow S J. Clinical characteristics associated with binge eating in obese females: a descriptive study. Int J Obes Relat Metab Disord. 1996;20:324-331. [pmid: 8680459].
236 Specker S, de Zwaan M, Raymond N, Mitchell J. Psychopathology in subgroups of obese women with and without binge eating disorder. Compr Psychiatry. 1994;35:185-190. [pmid: 8045108].
237 Brody M L, Walsh B T, Devlin M J. Binge eating disorder: reliability and validity of a new diagnostic category. J Consult Clin Psychol. 1994;62:381-386. [pmid: 8201077].
238 de Zwaan M, Nutzinger D O, Schoenbeck G. Binge eating in overweight women. Compr Psychiatry. 1992;33:256-261. [pmid: 1643867].
239 Kuehnel R H, Wadden T A. Binge eating disorder, weight cycling, and psychopathology. Int J Eat Disord. 1994;15:321-329. [pmid: 8032347].
240 Keefe P H, Wyshogrod D, Weinberger E, Agras W S. Binge eating and outcome of behavioral treatment of obesity: a preliminary report. Behav Res Ther. 1984;22:319-321. [pmid: 6590036].
241 Garner D M, Wooley S C. Confronting the failure of behavioral and dietary treatments for obesity. Clinl Psychol Rev. 1991;11:729-780.
242 Telch C F, Agras W S. The effects of a very low-calorie diet on binge eating. Behav Therapy. 1993;24:177-194.
243 Yanovski S Z, Sebring N G. Recorded food intake of obese women with binge eating disorder before and after weight loss. Int J Eat Disord. 1994;15:135-150. [pmid: 8173559].
244 Cash T F, Hicks K L. Being fat versus thinking fat: relationships with body image, eating behaviors, and well-being. Cogni Ther Res. 1990;14:327-341.
245 Collins J K. Methodology for the objective measurement of body image. Int J Eat Disord. 1987;6:393-399.
246 Collins J K, Beumont P J, Touyz S W, Krass J, et al. Variability in body shape, perception in anorexic, bulimic, obese, and control subjects. Int J Eat Disord. 1987;6:633-638.
247 Gardner R M, Martinez R, Sandoval Y. Obesity and body image: an evaluation of sensory and non-sensory components. Psychol Med. 1987;17:927-932. [pmid: 3432466].
248 Glucksman M L, Hirsch J. The response of obese patients to weight reduction. 3. The perception of body size. Psychosom Med. 1969;31:1-7. [pmid: 5775853].
249 Garner D M, Garfinkel P E, Stancer H C, Moldofsky H. Body image disturbances in anorexia nervosa and obesity. Psychosom Med. 1976;38:327-336. [pmid: 981491].
250 Grilo C M, Wilfley D E, Brownell K D, Rodin J. Teasing, body image, and self-esteem in a clinical sample of obese women. Addict Behav. 1994;19:443-450. [pmid: 7992678].
251 Mussell M P, Peterson C B, Weller C L, Crosby R D, de Zwaan M, Mitchell J E. Differences in body image and depression among obese women with and without binge eating disorder. Obes Res. 1996;4:431-439. [pmid: 8885207].
252 Stunkard A, Mendelson M. Obesity and the body image. I. Characteristics of disturbances in the body image of some obese persons. Am J Psychiatry. 1967;123:1296-1300. [pmid: 6021701].
253 Stunkard A, Burt V. Obesity and the body image. II. Age at onset of disturbances in the body image. Am J Psychiatry. 1967;123:1443-1447. [pmid: 6067060].
254 Cash TF. The psychology of physical appearance: aesthetics, attributes, and images. In: Cash TF, Pruzinsky T, eds. Body Images: Development, Deviance, and Change. New York: Guilford Press, 1990:51–79.
255 Tiggemann M, Rothblum E D. Gender differences in social consequences of perceived overweight in the United States and Australia. Sex Roles. 1988;18:75-86.
256 Rosen JC. Improving body image in obesity. In: Thompson JK, ed. Body Image, Eating Disorders, and Obesity. Washington, DC: American Psychological Association; 1996:425–440.
257 Kumanyika SK, Morssink CB. Cultural appropriateness of weight management programs. In: Dalton S, ed. Overweight and Weight Management: The Health Professional's Guide To Understanding and Practice. Gaithersburg, MD: Aspen Publishers; 1997:69–103.
258 Childress A C, Brewerton T D, Hodges E L, Jarrell M P. The Kids' Eating Disorders Survey (KEDS): a study of middle school students. J Am Acad Child Adolesc Psychiatry. 1993;32:843-850. [pmid: 8340308].
259 Kumanyika S, Wilson J F, Guilford-Davenport M. Weight-related attitudes and behaviors of black women. J Am Diet Assoc. 1993;93:416-422. [pmid: 8454809].
260 Powell A D, Kahn A S. Racial differences in women's desires to be thin. Int J Eat Disord. 1995;17:191-195. [pmid: 7757101].
261 Striegel-Moore R H, Schreiber G B, Pike K M, Wilfley D E, Rodin J. Drive for thinness in black and white preadolescent girls. Int J Eat Disord. 1995;18:59-69. [pmid: 7670444].
262 Desmond S M, Price J H, Hallinan C, Smith D. Black and white adolescents' perceptions of their weight. J Sch Health. 1989;59:353-358. [pmid: 2811315].
263 Kemper K A, Sargent R G, Drane J W, Valois R F, Hussey J W. Black and white females' preceptions of ideal body size and social norms. Obes Res. 1994;2:117-126. [pmid: 16353613].
264 Rand C S, Kuldau J M. Morbid obesity: a comparison between a general population and obesity surgery patients. Int J Obes Relat Metab Disord. 1993;17:657-661. [pmid: 8281224].
265 Stevens J, Kumanyika S K, Keil J E. Attitudes toward body size and dieting: differences between elderly black and white women. Am J Public Health. 1994;84:1322-1325. [pmid: 8059896].
266 Wilfley D E, Schreiber G B, Pike K M, Striegel-Moore R H, Wright D J, Rodin J. Eating disturbance and body image: a comparison of a community sample of adult black and white women. Int J Eat Disord. 1996;20:377-387. [pmid: 8953325].
267 Rucker C E, Cash T F. Body images, body-size perceptions, and eating behaviors among African-American and white college women. Int J Eating Disord. 1992;12:291-300.
268 Schreiber G G, Robins M, Striegel-Moore R, Obarzanek E, Morrison J A, Wright D J. Weight modification efforts reported by black and white preadolescent girls: National Heart, Lung, and Blood Institute Growth and Health Study. Pediatrics. 1996;98:63-70. [pmid: 8668414].
269 Rosen J C, Gross J. Prevalence of weight reducing and weight gaining in adolescent girls and boys. Health Psychol. 1987;6:131-147. [pmid: 3470177].
270 Gittelsohn J, Harris S B, Thorne-Lyman A L, Hanley A J, Barnie A, Zinman B. Body image concepts differ by age and sex in an Ojibway-Cree community in Canada. J Nutr. 1996;126:2990-3000. [pmid: 9001366].
271 Cooper R S, Ford E. Comparability of risk factors for coronary heart disease among blacks and whites in the NHANES-I Epidemiologic Follow-up Study. Ann Epidemiol. 1992;2:637-645. [pmid: 1342315].
272 Folsom A R, Burke G L, Byers C L, et al. Implications of obesity for cardiovascular disease in blacks: the CARDIA and ARIC studies. Am J Clin Nutr. 1991;53:1604S-1611S. [pmid: 2031493].
273 Fujimoto W Y, Newell-Morris L L, Grote M, Bergstrom R W, Shuman W P. Visceral fat obesity and morbidity: NIDDM and atherogenic risk in Japanese-American men and women. Int J Obes. 1991;15(Suppl2):41-44. [pmid: 1794937].
274 Galanis D J, McGarvey S T, Sobal J, Bausserman L, Levinson P D. Relations of body fat and fat distribution to the serum lipid, apolipoprotein and insulin concentrations of Samoan men and women. Int J Obes Relat Metab Disord. 1995;19:731-738. [pmid: 8589767].
275 Haffner S M, Diehl A K, Stern M P, Hazuda H P. Central adiposity and gallbladder disease in Mexican Americans. Am J Epidemiol. 1989;129:587-595. [pmid: 2916552].
276 Havas S, Fujimoto W, Close N, McCarter R, Keller J, Sherwin R. The NHLBI workshop on Hypertension in Hispanic Americans, Native Americans, and Asian/Pacific Islander Americans. Public Health Rep. 1996;111:451-458. [pmid: 8837635].
277 Howard B V, Lee E T, Cowan L D, et al. Coronary heart disease prevalence and its relation to risk factors in American Indians. The Strong Heart Study. Am J Epidemiol. 1995;142:254-268. [pmid: 7631630].
278 Lipton R B, Liao Y, Cao G, Cooper R S, McGee D. Determinants of incident non-insulin-dependent diabetes mellitus among blacks and whites in a national sample. The NHANES I Epidemiologic Follow-up Study. Am J Epidemiol. 1993;138:826-839. [pmid: 8237971].
279 Federation of American Societies for Experimental Biology. Life Sciences Research. Third Report on Nutrition Monitoring in the United States. Washington, DC: Interagency Board for Nutrition Monitoring and Related Research; 1995.
280 Ettinger W H, Wahl P W, Kuller L H, et al. Lipoprotein lipids in older people. Results from the Cardiovascular Health Study. The CHS Collaborative Research Group. Circulation. 1992;86:858-869. [pmid: 1516198].
281 Neser W B, Thomas J, Semenya K, Thomas D J, Gillum R F. Obesity and hypertension in a longitudinal study of black physicians: the Meharry Cohort Study. J Chronic Dis. 1986;39:105-113. [pmid: 3944222].
282 Schmidt-Nowara W W, Coultas D B, Wiggins C, Skipper B E, Samet J M. Snoring in a Hispanic-American population. Risk factors and association with hypertension and other morbidity. Arch Intern Med. 1990;150:597-601. [pmid: 2310278].
283 Warne D K, Charles M A, Hanson R L, et al. Comparison of body size measurements as predictors of NIDDM in Pima Indians. Diabetes Care. 1995;18:435-439. [pmid: 7497850].
284 Wei M, Gaskill S P, Haffner S M, Stern M P. Waist circumference as the best predictor of noninsulin dependent diabetes mellitus (NIDDM) compared to body mass index, waist/hip ratio, and other anthropometric measurements in Mexican Americans—a 7-year prospective study. Obes Res. 1997;5:16-23. [pmid: 9061711].
285 Lee I M, Manson J E, Hennekens C H, Paffenbarger R S Jr. Body weight and mortality. A 27-year follow-up of middle-aged men. JAMA. 1993;270:2823-2828. [pmid: 8133621].
286 Allison D B, Faith M S, Heo M, Kotler D P. Hypothesis concerning the U-shaped relation between body mass index and mortality. Am J Epidemiol. 1997;146:339-349. [pmid: 9270413].
287 Stevens J, Cai J, Pamuk E R, Williamson D F, Thun M J, Wood J L. The effect of age on the association between body-mass index and mortality. N Engl J Med. 1998;338:1-7. [pmid: 9414324].
288 Diehr P, Bild D E, Harris T B, Duxbury A, Siscovick D, Rossi M. Body mass index and mortality in nonsmoking older adults: The cardiovascular health study. Am J Public Health. 1998;88:623-629. [pmid: 9551005].
289 Cornoni-Huntley J C, Harris T B, Everett D F, et al. An overview of body weight of older persons, including the impact on mortality. The National Health and Nutrition Examination Survey I—Epidemiologic Follow-up Study. J Clin Epidemiol. 1991;44:743-753. [pmid: 1941025].
290 Harris T, Cook E F, Garrison R, Higgins M, Kannel W, Goldman L. Body mass index and mortality among nonsmoking older persons. The Framingham Heart Study. JAMA. 1988;259:1520-1524. [pmid: 3339789].
291 Baumgartner R N, Heymsfield S B, Roche A F. Human body composition and the epidemiology of chronic disease. Obes Res. 1995;3:73-95. [pmid: 7712363].
292 Losonczy K G, Harris T B, Cornoni-Huntley J, et al. Does weight loss from middle age to old age explain the inverse weight mortality relation in old age?. Am J Epidemiol. 1995;141:312-321. [pmid: 7840109].
293 Fried L P, Kronmal R A, Newman A B, et al. Risk factors for 5-year mortality in older adults (for the Cardiovascular Health Study Collaborative Research Group). JAMA. 1998;279:585-592. [pmid: 9486752].
294 Folsom A R, Kaye S A, Sellers T A, et al. Body fat distribution and 5-year risk of death in older women. JAMA. 1993;269:483-487. [pmid: 8419667].
295 Willett W C, Stampfer M, Manson J, VanItallie T. New weight guidelines for Americans: justified or injudicious?. Am J Clin Nutr. 1991;53:1102-1103. [pmid: 2021120].
296 Roche A F. Sarcopenia: a critical review of its measurements and health-related significance in the middle-aged and elderly. Am J Hum Biol. 1994;6:33-42.
297 Durazo-Arvizu R A, McGee D L, Cooper R S, Liao Y, Luke A. Mortality and optimal body mass index in a sample of the U.S. population. Am J Epidemiol. 1998;147:739-749. [pmid: 9554415].
Sorkin J D ,, Zonderman A B, Costa P T J r ,, Andres R. Twenty year follow-up of the NHANES I cohort: tests of methodologic hypotheses. Obes Res. 1996;4(Suppl 1):M46.
299 Stern M P, Patterson J K, Mitchell B D, Haffner S M, Hazuda H P. Overweight and mortality in Mexican Americans. Int J Obes. 1990;14:623-629. [pmid: 2228397].
300 Johnson J L, Heineman E F, Heiss G, Hames C G, Tyroler H A. Cardiovascular disease risk factors and mortality among black women and white women aged 40–64 years in Evans County, Georgia. Am J Epidemiol. 1986;123:209-220. [pmid: 3946371].
301 Stevens J, Keil J E, Rust P F, Tyroler H A, Davis C E, Gazes P C. Body mass index and body girths as predictors of mortality in black and white women. Arch Intern Med. 1992;152:1257-1262. [pmid: 1599355].
302 Tyroler H A, Knowles M G, Wing S B, et al. Ischemic heart disease risk factors and 20-year mortality in middle-age Evans County black males. Am Heart J. 1984;108:738-746. [pmid: 6475743].
303 Wienpahl J, Ragland D R, Sidney S. Body mass index and 15-year mortality in a cohort of black men and women. J Clin Epidemiol. 1990;43:949-960. [pmid: 2213083].
304 Durazo-Arvizu R, Cooper R S, Luke A, Prewitt T E, Liao Y, McGee D L. Relative weight and mortality in U.S. blacks and whites: findings from representative national population samples. Ann Epidemiol. 1997;7:383-395. [pmid: 9279447].
305 Hodge A M, Dowse G K, Collins V R, Zimmet P Z. Mortality in Micronesian Nauruans and Melanesian and Indian Fijians is not associated with obesity. Am J Epidemiol. 1996;143:442-455. [pmid: 8610659].
306 Hanson R L, McCance D R, Jacobsson L T, et al. The U-shaped association between body mass index and mortality: relationship with weight gain in a Native-American population. J Clin Epidemiol. 1995;48:903-916. [pmid: 7782799].
307 Pettitt D J, Lisse J R, Knowler W C, Bennett P H. Mortality as a function of obesity and diabetes mellitus. Am J Epidemiol. 1982;115:359-366. [pmid: 7064971].
308 Andres R, Muller D C, Sorkin J D. Long-term effects of change in body weight on all-cause mortality. A review. Ann Intern Med. 1993;119:737-743. [pmid: 8363208].
309 Weight cycling. National Task Force on the Prevention and Treatment of Obesity. JAMA. 1994;272:1196-1202. [pmid: 7741844].
310 Williamson D F, Pamuk E R. The association between weight loss and increased longevity. A review of the evidence. Ann Intern Med. 1993;119:731-736. [pmid: 8363207].
311 Williamson D F. “Weight cycling” and mortality: how do the epidemiologists explain the role of intentional weight loss?. J Am Coll Nutr. 1996;15:6-13. [pmid: 8632117].
312 Williamson D F. Intentional weight loss: patterns in the general population and its association with morbidity and mortality. Int J Obes Relat Metab Disord. 1997;21(Suppl 1):S14-S19. [pmid: 9130036].
313 French S A, Jeffery R W, Folsom A R, Williamson D F, Byers T. Weight variability in a population-based sample of older women: reliability and intercorrelation of measures. Int J Obes Relat Metab Disord. 1995;19:22-29. [pmid: 7719387].
314 French S A, Jeffery R W, Folsom A R, Williamson D F, Byers T. History of intentional and unintentional weight loss in a population-based sample of women aged 55 to 69 years. Obes Res. 1995;3:163-170. [pmid: 7719962].
315 French S A, Jeffery R W, Folsom A R, Williamson D F, Byers T. Relation of weight variability and intentionality of weight loss to disease history and health-related variables in a population-based sample of women aged 55–69 years. Am J Epidemiol. 1995;142:1306-1314. [pmid: 7503051].
316 Meltzer A A, Everhart J E. Unintentional weight loss in the United States. Am J Epidemiol. 1995;142:1039-1046. [pmid: 7485049].
317 Singh R B, Rastogi S S, Verma R, et al. Randomised controlled trial of cardioprotective diet in patients with recent acute myocardial infarction: results of 1-year follow up. BMJ. 1992;304:1015-1019. [pmid: 1586782].
318 Williamson D F, Pamuk E, Thun M, Flanders D, Byers T, Heath C. Prospective study of intentional weight loss and mortality in never-smoking overweight US white women aged 40–64 years. Am J Epidemiol. 1995;141:1128-1141. [pmid: 7771451].
319 Williamson DF, Pamuk E, Thun M, et al. Prospective study of international weight loss and mortality in overweight men aged 40–64 years. Obes Res. 1997;5:94S. [abstract].
320 Sjostrom L, Larsson B, Backman L, et al. Swedish obese subjects (SOS). Recruitment for an intervention study and a selected description of the obese state. Int J Obes Relat Metab Disord. 1992;16:465-479. [pmid: 1322873].
321 Sjostrom C D, Lissner L, Sjostrom L. Relationships between changes in body composition and changes in cardiovascular risk factors: the SOS intervention study. Obes Res. 1997;5:519-530. [pmid: 9449135].
322 Sjostrom L. Natural history of massive obesity. Obes Res. 1995;3:317S. [abstract].
323 Sobal J, Stunkard A J. Socioeconomic status and obesity: A review of the literature. Psychol Bull. 1989;105:260-275. [pmid: 2648443].
324 Kumanyika S K. Obesity in minority populations: An epidemiologic assessment. Obes Res. 1994;2:166-182. [pmid: 16353618].
325 Ravussin E, Valencia M E, Esparza J, Bennett P H, Schultz L O. Effects of a traditional lifestyle on obesity in Pima Indians. Diabetes Care. 1994;17:1067-1074. [pmid: 7988310].
326 Kawate R, Yamakido M, Nishimoto Y. Migrant studies among the Japanese in Hiroshima and Hawaii. Proc 10th Congr Int Diabetes Federation. 1980:526–531.
327 Kawate R, Yamakido M, Nishimoto Y. Diabetes mellitus and its vascular complications in Japanese migrants on the Island of Hawaii. Diabetes Care. 1979;29:161-170. [pmid: 520120].
328 Taylor R, Bennett P, Uili R, Joffres N, Levey S, Zimmet P. Diabetes in Wallis Polynesians: a comparison of residents of Wallis Island and first generation migrants of Noumea. Diabetes Res Clin Pract. 1985;1:169-178. [pmid: 3836104].
329 Bouchard C, Perusse L, Leblanc C, Tremblay A, Theriault G. Inheritance of the amount and distribution of human body fat. Int J Obes. 1988;12:205-215. [pmid: 3391737].
330 Tambs K, Moum T, Eaves L, et al. Genetics and environmental contributions to the variance of the body mass index in a Norwegian sample of first-degree and second-degree relatives. Am J Human Biology. 1991;3:257-268.
331 Vogler G P, Sorensen T I, Stunkard A J, Srinivasan M R, Rao D C. Influences of genes and shared family environment on adult body mass index assessed in an adoption study by a comprehensive path model. Int J Obes Relat Metab Disord. 1995;19:40-45. [pmid: 7719389].
332 Stunkard A J, Harris J R, Pedersen N L, McClearn G E. The body-mass index of twins who have been reared apart. N Engl J Med. 1990;322:1483-1487. [pmid: 2336075].
333 Allison D B, Kaprio J, Korkeila M, Koskenvuo M, Neale M C, Hayakawa K. The heritability of body mass index among an international sample of monozygotic twins reared apart. Int J Obes Relat Metab Disord. 1996;20:501-506. [pmid: 8782724].
334 Maes H H M, Neale M C, Eaves L J. Genetic and environmental factors in relative body weight and human adiposity. Behav Genet. 1997;27:325-351. [pmid: 9519560].
335 Allison DB. Methodological issues in obesity research: examples from new directions in assessment and management. In: VanItallie TB, Simopoulos AP, eds. Obesity. Philadelphia: Charles Press; 1995:129–132.
336 Allison DB, Pi-Sunyer FX. Obesity Treatment: Establishing Goals, Improving Outcomes, and Reviewing the Research Agenda. New York: Plenum Press; 1995.
337 Allison D B, Faith M S, Nathan J S. Risch's lambda values for human obesity. Int J Obes. 1996;20:990-999.
338 Lee J H, Reed D R, Price R A. Familial risk ratios for extreme obesity: implications for mapping human obesity genes. Int J Obes Relat Metab Disord. 1997;21:935-940. [pmid: 9347413].
339 Perusse L, Chagnon Y C, Dionne F T, Bouchard C. The human obesity gene map: the 1996 update. Obes Res. 1997;5:49-61. [pmid: 9061716].
340 Zhang Y, Proenca R, Maffei M, Barone M, Leopold L, Friedman J M. Positional cloning of the mouse obese gene and its human homologue. Nature. 1994;372:425-432. [pmid: 7984236].
341 Tartaglia L A, Dembski M, Weng X, et al. Identification and expression cloning of leptin receptor, OB-R. Cell. 1995;83:1263-1271. [pmid: 8548812].
342 Montague C T, Farooqi I S, Whitehead J P, et al. Congenital leptin deficiency is associated with severe early-onset obesity in humans. Nature. 1997;387:903-908. [pmid: 9202122].
343 Bouchard C, Perusse L, Rice T, Rao DC. The genetics of human obesity. In: Bray GA, Bouchard C, James WPT, eds. Handbook of Obesity. New York: M. Dekker; 1998: Chapter 10.
344 Bouchard C, Tremblay A. Genetic effects in human energy expenditure components. Int J Obes. 1990;14(Suppl 1):49-55. [pmid: 2228417].
345 Bouchard C, Tremblay A, Despres J P, et al. The response to long-term overfeeding in identical twins. N Engl J Med. 1990;322:1477-1482. [pmid: 2336074].
346 Anderssen S, Holme I, Urdal P, Hjermann I. Diet and exercise intervention have favourable effects on blood pressure in mild hypertensives: the Oslo Diet and Exercise Study (ODES). Blood Press. 1995;4:343-349. [pmid: 8746601].
347 Croft P R, Brigg D, Smith S, Harrison C B, Branthwaite A, Collins M F. How useful is weight reduction in the management of hypertension?. J R Coll Gen Pract. 1986;36:445-448. [pmid: 3440987].
348 Davis B R, Blaufox M D, Oberman A, et al. Reduction in long-term antihypertensive medication requirements. Effects of weight reduction by dietary intervention in overweight persons with mild hypertension. Arch Intern Med. 1993;153:1773-1782. [pmid: 8333814].
349 Fagerberg B, Andersson O K, Isaksson B, Bjorntorp P. Blood pressure control during weight reduction in obese hypertensive men: separate effects of sodium and energy restriction. BMJ. 1984;288:11-14. [pmid: 6418295].
350 Grimm R H Jr, Cohen J D, Smith W M, Falvo-Gerard L, Neaton J D. Hypertension management in the Multiple Risk Factor Intervention Trial (MRFIT). 6-year intervention results for men in special intervention and usual care groups. Arch Intern Med. 1985;145:1191-1199. [pmid: 3893343].
351 Haynes R B, Harper A C, Costley S R, et al. Failure of weight reduction to reduce mildly elevated blood pressure: a randomized trial. J Hypertens. 1984;2:535-539. [pmid: 6397541].
352 Heyden S. The workingman's diet. II. Effect of weight reduction in obese patients with hypertension, diabetes, hyperuricemia and hyperlipidemia. Nutr Metab. 1978;22:141-159. [pmid: 634508].
353 Kumanyika SK, Bahnson J, Bottom J, et al. Race and sex influences on the efficacy of non-pharmologic step-down therapy in hypertensive older adults. Can J Cardiol. 1997;13 (Suppl B):369B [abstract].
354 Langford H G, Blaufox M D, Oberman A, et al. Dietary therapy slows the return of hypertension after stopping prolonged medication. JAMA. 1985;253:657-664. [pmid: 3881608].
355 Langford H G, Davis B R, Blaufox D, et al. Effect of drug and diet treatment of mild hypertension on diastolic blood pressure. The TAIM Research Group. Hypertension. 1991;17:210-217. [pmid: 1671380].
356 MacMahon S W, Macdonald G J, Bernstein L, Andrews G, Blacket R B. A randomized controlled trial of weight reduction and metoprolol in the treatment of hypertension in young overweight patients. Clin Exp Pharmacol Physiol. 1985;12:267-271. [pmid: 3896595].
357 Ramsay L E, Ramsay M H, Hettiarachchi J, Davies D L, Winchester J. Weight reduction in a blood pressure clinic. BMJ. 1978;2:244-245. [pmid: 678886].
358 Reisin E, Abel R, Modan M, Silverberg D S, Eliahou H E, Modan B. Effect of weight loss without salt restriction on the reduction of blood pressure in overweight hypertensive patients. N Engl J Med. 1978;298:1-6. [pmid: 337144].
359 Stamler R, Stamler J, Grimm R, et al. Nutritional therapy for high blood pressure. Final report of a 4-year randomized controlled trial—the Hypertension Control Program. JAMA. 1987;257:1484-1491. [pmid: 3546747].
360 Wassertheil-Smoller S, Langford H G, Blaufox M D, et al. Effective dietary intervention in hypertensives: sodium restriction and weight reduction. J Am Diet Assoc. 1985;85:423-430. [pmid: 3884691].
361 Whelton PK, Applegate WB, Ettiger WH, et al. Efficacy of weight loss and reduced sodium intake in the Trial of Nonpharmacologic Interventions in the Elderly (TONE). Circulation. 1996;94 (Suppl I):I-178 [abstract].
362 Agurs-Collins T D, Kumanyika S K, Have T R, Adams-Campbell L L. A randomized controlled trial of weight reduction and exercise for diabetes management in older African-American subjects. Diabetes Care. 1997;20:1503-1511. [pmid: 9314625].
363 Fortmann S P, Haskell W L, Wood P D. Effects of weight loss on clinic and ambulatory blood pressure in normotensive men. Am J Cardiol. 1988;62:89-93. [pmid: 3381757].
364 Hakala P, Karvetti R L. Weight reduction on lactovegetarian and mixed diets. Changes in weight, nutrient intake, skinfold thicknesses and blood pressure. Eur J Clin Nutr. 1989;43:421-430. [pmid: 2743965].
365 Hellenius M L, de Faire U, Berglund B, Hamsten A, Krakau I. Diet and exercise are equally effective in reducing risk for cardiovascular disease. Results of a randomized controlled study in men with slightly to moderately raised cardiovascular risk factors. Atherosclerosis. 1993;103:81-91. [pmid: 8280188].
366 Hypertension Prevention Trial Research Group. The Hypertension Prevention Trial: three-year effects of dietary changes on blood pressure. Arch Intern Med. 1990;150:153-162. [pmid: 2404477].
367 Jeffery R W, Wing R R, Thorson C, et al. Strengthening behavioral interventions for weight loss: a randomized trial of food provision and monetary incentives. J Consult Clin Psychol. 1993;61:1038-1045. [pmid: 8113481].
368 Karvetti R L, Hakala P. A 7-year follow-up of a weight reduction programme in Finnish primary health care. Eur J Clin Nutr. 1992;46:743-752. [pmid: 1425528].
369 Katzel L I, Bleecker E R, Colman E G, Rogus E M, Sorkin J D, Goldberg A P. Effects of weight loss vs aerobic exercise training on risk factors for coronary disease in healthy, obese, middle-aged and older men. A randomized controlled trial. JAMA. 1995;274:1915-1921. [pmid: 8568984].
370 Puddey I B, Parker M, Beilin L J, Vandongen R, Masarei J R. Effects of alcohol and caloric restrictions on blood pressure and serum lipids in overweight men. Hypertension. 1992;20:533-541. [pmid: 1356922].
371 Reid C M, Dart A M, Dewar E M, Jennings G L. Interactions between the effects of exercise and weight loss on risk factors, cardiovascular haemodynamics and left ventricular structure in overweight subjects. J Hypertens. 1994;12:291-301. [pmid: 8021483].
372 Rocchini A P, Katch V, Schork A, Kelch R P. Insulin and blood pressure during weight loss in obese adolescents. Hypertension. 1987;10:267-273. [pmid: 3305355].
373 Simkin-Silverman L, Wing R R, Hansen D H, et al. Prevention of cardiovascular risk factor elevations in healthy premenopausal women. Prev Med. 1995;24:509-517. [pmid: 8524727].
374 Stamler R, Stamler J, Gosch F C, et al. Primary prevention of hypertension by nutritional-hygienic means. Final report of a randomized, controlled trial. JAMA. 1989;262:1801-1807. [pmid: 2778913].
375 Stefanick M L, Mackey S, Sheehan M, Ellsworth N, Haskell W L, Wood P D. Effects of the NCEP Step 2 diet and exercise on lipoprotein in postmenopausal women and men with low HDL-cholesterol and high LDL-cholesterol. New Engl J Med. 1998;339:12-20. [pmid: 9647874].
376 Stevens V J, Corrigan S A, Obarzanek E, et al. Weight loss intervention in phase 1 of the Trials of Hypertension Prevention. The TOHP Collaborative Research Group. Arch Intern Med. 1993;153:849-858. [pmid: 8466377].
377 Svendsen O L, Hassager C, Christiansen C. Effect of an energy-restrictive diet, with or without exercise, on lean tissue mass, resting metabolic rate, cardiovascular risk factors, and bone in overweight postmenopausal women. Am J Med. 1993;95:131-140. [pmid: 8356979].
378 The effects of nonpharmacologic interventions on blood pressure of persons with high normal levels. Results of the Trials of Hypertension Prevention, Phase I. JAMA. 1992;267:1213-1220. [pmid: 1586398].
379 Trials of Hypertension Prevention Collaborative Research Group. Effects of weight loss and sodium reduction intervention on blood pressure and hypertension incidence in overweight people with high-normal blood pressure. The Trials of Hypertension Prevention, phase II. Arch Intern Med. 1997;157:657-667. [pmid: 9080920].
380 Wood P D, Stefanick M L, Williams P T, Haskell W L. The effects on plasma lipoproteins of a prudent weight-reducing diet, with or without exercise, in overweight men and women. N Engl J Med. 1991;325:461-466. [pmid: 1852180].
381 MacMahon S, Cutler J, Brittain E, Higgins M. Obesity and hypertension: epidemiological and clinical issues. Eur Heart J. 1987;8(Suppl B):57-70. [pmid: 3301356].
382 Whelton P K, Appel L J, Espeland M A, et al. Sodium reduction and weight loss in the treatment of hypertension in older persons: A randomized controlled trial of nonpharmacologic interventions in the elderly (TONE). JAMA. 1998;279:839-846. [pmid: 9515998].
383 Cutler J A. Randomized clinical trials of weight reduction in nonhypertensive persons. Ann Epidemiol. 1991;1:363-370. [pmid: 1669517].
384 Svendsen O L, Hassager C, Christiansen C. Six months' follow-up on exercise added to a short-term diet in overweight postmenopausal women—effects on body composition, resting metabolic rate, cardiovascular risk factors and bone. Int J Obes Relat Metab Disord. 1994;18:692-698. [pmid: 7866465].
385 Steven VJ. Weight loss and blood pressure changes over three years: results of the Trials of Hypertension Prevention (TOHP) Phase II. In: Cardiovascular Health: Coming Together for the 21st Century. A National Conference. 1998 Feb 19–21; San Francisco, CA: National Heart, Lung, and Blood Institute; 1998. Abstract R.6F.
386 Bremer J M, Scott R S, Lintott C J. Dexfenfluramine reduces cardiovascular risk factors. Int J Obes Relat Metab Disord. 1994;18:199-205. [pmid: 8044193].
387 Ditschuneit H H, Flechtner-Mors M, Adler G. The effects of dexfenfluramine on weight loss and cardiovascular risk factors in female patients with upper and lower body obesity. J Cardiovasc Risk. 1996;3:397-403. [pmid: 8946272].
388 Bone HG, Reedy KR, Sherwin RS. FDA Orlistat Transcript. Endocrinologic and Metabolic Drugs Advisory Committee Meeting # 67. 1997.
389 Bone HG, Reedy KR, Colley CA. FDA Sibutramine Transcript. Endocrinologic and Metabolic Drugs Advisory Committee Meeting # 64. 1996.
390 Mathus-Vliegen E M, van de Voorde K, Kok A M, Res A M. Dexfenfluramine in the treatment of severe obesity: a placebo-controlled investigation of the effects on weight loss, cardiovascular risk factors, food intake and eating behaviour. J Intern Med. 1992;232:119-127. [pmid: 1506807].
391 Mathus-Vliegen E M. Prolonged surveillance of dexfenfluramine in severe obesity. Neth J Med. 1993;43:246-253. [pmid: 8107932].
392 O'Connor H T, Richman R M, Steinbeck K S, Caterson I D. Dexfenfluramine treatment of obesity: a double blind trial with posttrial followup. Int J Obes Relat Metab Disord. 1995;19:181-189. [pmid: 7780494].
393 Pfohl M, Luft D, Blomberg I, Schmulling R M. Long-term changes of body weight and cardiovascular risk factors after weight reduction with group therapy and dexfenfluramine. Int J Obes Relat Metab Disord. 1994;18:391-395. [pmid: 8081430].
394 Swinburn B A, Carmichael H E, Wilson M R. Dexfenfluramine as an adjunct to a reduced-fat, ad libitum diet: effects on body composition, nutrient intake and cardiovascular risk factors. Int J Obes Relat Metab Disord. 1996;20:1033-1040. [pmid: 8923161].
395 Weintraub M, Sundaresan P R, Madan M, et al. Long-term weight control study. I (weeks 0 to 34). The enhancement of behavior modification, caloric restriction, and exercise by fenfluramine plus phentermine versus placebo. Clin Pharmacol Ther. 1992;51:586-594. [pmid: 1587072].
396 Arroll B, Beaglehole R. Exercise for hypertension. Lancet. 1993;341:1248-1249. [pmid: 8098398].
397 Fagard R H. Physical fitness and blood pressure. J Hypertens Suppl. 1993;11 Suppl 5:S47-S52. [pmid: 8158433].
398 Kelley G, Tran Z V. Aerobic exercise and normotensive adults: a meta-analysis. Med Sci Sports Exerc. 1995;27:1371-1377. [pmid: 8531607].
399 Dengel J L, Katzel L I, Goldberg A P. Effect of an American Heart Association diet, with or without weight loss, on lipids in obese middle-aged and older men. Am J Clin Nutr. 1995;62:715-721. [pmid: 7572698].
400 Jalkanen L. The effect of a weight reduction program on cardiovascular risk factors among overweight hypertensives in primary health care. Scand J Soc Med. 1991;19:66-71. [pmid: 1925430].
401 King A C, Haskell W L, Taylor C B, Kraemer H C, DeBusk R F. Group- vs home-based exercise training in healthy older men and women. A community-based clinical trial. JAMA. 1991;266:1535-1542. [pmid: 1880885].
402 Marniemi J, Seppanen A, Hakala P. Long-term effects on lipid metabolism of weight reduction on lactovegetarian and mixed diet. Int J Obes. 1990;14:113-125. [pmid: 2111292].
403 Nilsson P M, Lindholm L H, Schersten B F. Lifestyle changes improve insulin resistance in hyperinsulinaemic subjects: a 1-year intervention study of hypertensives and normotensives in Dalby. J Hypertens. 1992;10:1071-1078. [pmid: 1328367].
404 Ronnemaa T, Marniemi J, Puukka P, Kuusi T. Effects of long-term physical exercise on serum lipids, lipoproteins and lipid metabolizing enzymes in type 2 (non-insulin-dependent) diabetic patients. Diabetes Res. 1988;7:79-84. [pmid: 3396267].
405 Schuler G, Hambrecht R, Schlierf G, et al. Regular physical exercise and low-fat diet. Effects on progression of coronary artery disease. Circulation. 1992;86:1-11. [pmid: 1617762].
406 Wood P D, Stefanick M L, Dreon D M, et al. Changes in plasma lipids and lipoproteins in overweight men during weight loss through dieting as compared with exercise. N Engl J Med. 1988;319:1173-1179. [pmid: 3173455].
407 Drent M L, van der Veen E A. Lipase inhibition: a novel concept in the treatment of obesity. Int J Obes Relat Metab Disord. 1993;17:241-244. [pmid: 8387973].
408 O'Kane M, Wiles P G, Wales J K. Fluoxetine in the treatment of obese type 2 diabetic patients. Diabet Med. 1994;11:105-110. [pmid: 8181239].
409 Emery E M, Schmid T L, Kahn H S, Filozof P P. A review of the association between abdominal fat distribution, health outcome measures, and modifiable risk factors. Am J Health Promot. 1993;7(5):342-353. [pmid: 10148711].
410 Bjorntorp P. Abdominal fat distribution and disease: an overview of epidemiological data. Ann Med. 1992;24:15-18. [pmid: 1575956].
411 Leon AS. Physical Activity and Cardiovascular Health: A National Consensus. IL: Human Kinetics; 1997.
412 Hjermann I, Leren P, Norman N, Helgeland A, Holme I. Serum insulin response to oral glucose load during a dietary intervention trial in healthy coronary high risk men: the Oslo study. Scand J Clin Lab Invest. 1980;40:89-94. [pmid: 6988933].
413 Heller S R, Clarke P, Daly H, et al. Group education for obese patients with type 2 diabetes: greater success at less cost. Diabet Med. 1988;5:552-556. [pmid: 2974778].
414 Manning R M, Jung R T, Leese G P, Newton R W. The comparison of four weight reduction strategies aimed at overweight diabetic patients. Diabet Med. 1995;12:409-415. [pmid: 7648803].
415 Colman E, Katzel L I, Rogus E, Coon P, Muller D, Goldberg A P. Weight loss reduces abdominal fat and improves insulin action in middle-aged and older men with impaired glucose tolerance. Metabolism. 1995;44:1502-1508. [pmid: 7476341].
416 Fujioka S, Matsuzawa Y, Tokunaga K, et al. Improvement of glucose and lipid metabolism associated with selective reduction of intra-abdominal visceral fat in premenopausal women with visceral fat obesity. Int J Obes. 1991;15:853-859. [pmid: 1794928].
417 Marks S J, Moore N R, Clark M L, Strauss B J, Hockaday T D. Reduction of visceral adipose tissue and improvement of metabolic indices: effect of dexfenfluramine in NIDDM. Obes Res. 1996;4:1-7. [pmid: 8787932].
418 van der Merwe M T, Wing J R, Celgow L H, et al. Metabolic indices in relation to body composition changes during weight loss on dexfenfluramine in obese women from two South African ethnic groups. Int J Obes Relat Metab Disord. 1996;20:768-776. [pmid: 8856402].
419 Ronnemaa T, Mattila K, Lehtonen A, Kallio V. A controlled randomized study on the effect of long-term physical exercise on the metabolic control in type 2 diabetic patients. Acta Med Scand. 1986;220:219-224. [pmid: 3535397].
420 Han T S, van Leer E M, Seidell J C, Lean M E. Waist circumference action levels in the identification of cardiovascular risk factors: prevalence study in a random sample. BMJ. 1995;311:1401-1405. [pmid: 8520275].
421 Pouliot M C, Despres J P, Lemieux S, et al. Waist circumference and abdominal sagittal diameter: best simple anthropometric indexes of abdominal visceral adipose tissue accumulation and related cardiovascular risk in men and women. Am J Cardiol. 1994;73:460-468. [pmid: 8141087].
422 van der Kooy K, Leenen R, Seidell J C, Deurenberg P, Droop A, Bakker C J. Waist-hip ratio is a poor predictor of changes in visceral fat. Am J Clin Nutr. 1993;57:327-333. [pmid: 8438766].
423 Bouchard C, Tremblay A, Despres J P, et al. The response to exercise with constant energy intake in identical twins. Obes Res. 1994;2:400-410. [pmid: 16358397].
424 Leenen R, van der Kooy K, Deurenberg P, et al. Visceral fat accumulation in obese subjects: relation to energy expenditure and response to weight loss. Am J Physiol. 1992;263:E913-E919. [pmid: 1443124].
425 Stallone D D, Stunkard A J, Wadden T A, Foster G D, Boorstein J, Arger P. Weight loss and body fat distribution: a feasibility study using computed tomography. Int J Obes. 1991;15:775-780. [pmid: 1778662].
426 Ross R, Rissanen J, Pedwell H, Clifford J, Shragge P. Influence of diet and exercise on skeletal muscle and visceral adipose tissue in men. J Appl Physiol. 1996;81:2445-2455. [pmid: 9018491].
427 Ross R, Rissanen J. Mobilization of visceral and subcutaneous adipose tissue in response to energy restriction and exercise. Am J Clin Nutr. 1994;60:695-703. [pmid: 7942575].
428 van der Kooy K, Leenen R, Seidell J C, Deurenberg P, Hautvast J G. Effect of a weight cycle on visceral fat accumulation. Am J Clin Nutr. 1993;58:853-857. [pmid: 8249866].
429 Dowling H J, Pi-Sunyer F X. Race-dependent health risks of upper body obesity. Diabetes. 1993;42:537-543. [pmid: 8454103].
430 Kissebah A H, Vydelingum N, Murray R, et al. Relation of body fat distribution to metabolic complications of obesity. J Clin Endocrinol Metab. 1982;54:254-260. [pmid: 7033275].
431 Berglund A, Andersson O K, Berglund G, Fagerberg B. Antihypertensive effect of diet compared with drug treatment in obese men with mild hypertension. BMJ. 1989;299:480-485. [pmid: 2507028].
432 Frey-Hewitt B, Vranizan K M, Dreon D M, Wood P D. The effect of weight loss by dieting or exercise on resting metabolic rate in overweight men. Int J Obes. 1990;14:327-334. [pmid: 2361810].
433 Oberman A, Wassertheil-Smoller S, Langford H G, et al. Pharmacologic and nutritional treatment of mild hypertension: changes in cardiovascular risk status. Ann Intern Med. 1990;112:89-95. [pmid: 1967210].
434 Hammer R L, Barrier C A, Roundy E S, Bradford J M, Fisher A G. Calorie-restricted low-fat diet and exercise in obese women. Am J Clin Nutr. 1989;49:77-85. [pmid: 2912014].
435 Marks B L, Ward A, Morris D H, Castellani J, Rippe J M. Fat-free mass is maintained in women following a moderate diet and exercise program. Med Sci Sports Exerc. 1995;27:1243-1251. [pmid: 8531622].
436 Wadden T A, Sternberg J A, Letizia K A, Stunkard A J, Foster G D. Treatment of obesity by very low calorie diet, behavior therapy, and their combination: a five-year perspective. Int J Obes. 1989;13(Suppl 2):39-46. [pmid: 2613427].
437 Wadden T A, Foster G D, Letizia K A. One-year behavioral treatment of obesity: comparison of moderate and severe caloric restriction and the effects of weight maintenance therapy. J Consult Clin Psychol. 1994;62:165-171. [pmid: 8034818].
438 Wadden T A, Foster G D, Letizia K A, Mullen J L. Long-term effects of dieting on resting metabolic rate in obese outpatients. JAMA. 1990;264:707-711. [pmid: 2374273].
439 Wing R R, Blair E H, Bononi P, Marcus M D, Watanabe R, Bergman R N. Caloric restriction per se is a significant factor in improvements in glycemic control and insulin sensitivity during weight loss in obese NIDDM patients. Diabetes Care. 1994;17:30-36. [pmid: 8112186].
440 de Bont A J, Baker I A, St. Leger A S, et al. A randomised controlled trial of the effect of low-fat diet advice on dietary response in insulin-independent diabetic women. Diabetologia. 1981;21:529-533. [pmid: 7040142].
441 Jeffery R W, Hellerstedt W L, French S A, Baxter J E. A randomized trial of counseling for fat restriction versus calorie restriction in the treatment of obesity. Int J Obes Relat Metab Disord. 1995;19:132-137. [pmid: 7735340].
442 Schlundt D G, Hill J O, Pope-Cordle J, Arnold D, Virts K L, Katahn M. Randomized evaluation of a low fat ad libitum carbohydrate diet for weight reduction. Int J Obes Relat Metab Disord. 1993;17:623-629. [pmid: 8281220].
443 Shah M, McGovern P, French S, Baxter J. Comparison of a low-fat, ad libitum complex-carbohydrate diet with a low-energy diet in moderately obese women. Am J Clin Nutr. 1994;59:980-984. [pmid: 8172104].
444 Sheppard L, Kristal A R, Kushi L H. Weight loss in women participating in a randomized trial of low-fat diets. Am J Clin Nutr. 1991;54:821-828. [pmid: 1951152].
445 Bertram S R, Venter I, Stewart R I. Weight loss in obese women—exercise vs. dietary education. S Afr Med J. 1990;78:15-18. [pmid: 2363076].
446 Verity L S, Ismail A H. Effects of exercise on cardiovascular disease risk in women with NIDDM. Diabetes Res Clin Pract. 1989;6:27-35. [pmid: 2649339].
447 King A C, Haskell W L, Young D R, Oka R K, Stefanick M L. Long-term effects of varying intensities and formats of physical activity on participation rates, fitness, and lipoproteins in men and women aged 50 to 65 years. Circulation. 1995;91:2596-2604. [pmid: 7743622].
448 Gordon N F, Scott C B, Levine B D. Comparison of single versus multiple lifestyle interventions: are the antihypertensive effects of exercise training and diet-induced weight loss additive?. Am J Cardiol. 1997;79:763-767. [pmid: 9070555].
449 Garrow J S, Summerbell C D. Meta-analysis: effect of exercise, with or without dieting, on the body composition of overweight subjects. Eur J Clin Nutr. 1995;49:1-10. [pmid: 7713045].
450 Miller W C, Lindeman A K, Wallace J, Niederpruem M. Diet composition, energy intake, and exercise in relation to body fat in men and women. Am J Clin Nutr. 1990;52:426-430. [pmid: 2393005].
451 Fitzgerald S J, Kriska A M, Pereira M A, de Courten M P. Associations among physical activity, television watching, and obesity in adult Pima Indians. Med Sci Sports Exerc. 1997;29:910-915. [pmid: 9243490].
452 Klesges R C, Eck L H, Isbell T R, Fulliton W, Hanson C L. Physical activity, body composition, and blood pressure: a multimethod approach. Med Sci Sports Exerc. 1991;23:759-765. [pmid: 1886487].
453 Tremblay A, Despres J P, Leblanc C, et al. Effect of intensity of physical activity on body fatness and fat distribution. Am J Clin Nutr. 1990;51:153-157. [pmid: 2305702].
454 French S A, Jeffery R W, Forster J L, McGovern P G, Kelder S H, Baxter J E. Predictors of weight change over two years among a population of working adults: the Healthy Worker Project. Int J Obes Relat Metab Disord. 1994;18:145-154. [pmid: 8186811].
455 Williams P T. Evidence for the incompatibility of age-neutral overweight and age- neutral physical activity standards from runners. Am J Clin Nutr. 1997;65:1391-1396. [pmid: 9129467].
456 Ewbank P P, Darga L L, Lucas C P. Physical activity as a predictor of weight maintenance in previously obese subjects. Obes Res. 1995;3:257-263. [pmid: 7627774].
457 Klesges R C, Klesges L M, Haddock C K, Eck L H. A longitudinal analysis of the impact of dietary intake and physical activity on weight change in adults. Am J Clin Nutr. 1992;55:818-822. [pmid: 1550064].
458 Ching P L, Willett W C, Rimm E B, Colditz G A, Gortmaker S L, Stampfer M J. Activity level and risk of overweight in male health professionals. Am J Public Health. 1996;86:25-30. [pmid: 8561237].
459 Williamson D F, Madans J, Anda R F, Kleinman J C, Kahn H S, Byers T. Recreational physical activity and ten-year weight change in a US national cohort. Int J Obes Relat Metab Disord. 1993;17:279-286. [pmid: 8389337].
460 Kawachi I, Troisi R J, Rotnitzky A G, Coakley E H, Colditz G A. Can physical activity minimize weight gain in women after smoking cessation?. Am J Public Health. 1996;86:999-1004. [pmid: 8669525].
461 Bild D E, Sholinsky P, Smith D E, Lewis C E, Hardin J M, Burke G L. Correlates and predictors of weight loss in young adults: the CARDIA study. Int J Obes Relat Metab Disord. 1996;20:47-55. [pmid: 8788322].
462 Kayman S, Bruvold W, Stern J S. Maintenance and relapse after weight loss in women: behavioral aspects. Am J Clin Nutr. 1990;52:800-807. [pmid: 2239754].
463 Grodstein F, Levine R, Troy L, Spencer T, Colditz G A, Stampfer M J. Three-year follow-up of participants in a commercial weight loss program. Can you keep it off?. Arch Intern Med. 1996;156:1302-1306. [pmid: 8651838].
464 Seidell J C. Environmental influences on regional fat distribution. Int J Obes. 1991;15:31-35. [pmid: 1794935].
465 Kaye S A, Folsom A R, Prineas R J, Potter J D, Gapstur S M. The association of body fat distribution with lifestyle and reproductive factors in a population study of postmenopausal women. Int J Obes. 1990;14:583-591. [pmid: 2228393].
466 Slattery M L, McDonald A, Bild D E, et al. Associations of body fat and its distribution with dietary intake, physical activity, alcohol, and smoking in blacks and whites. Am J Clin Nutr. 1992;55:943-949. [pmid: 1570801].
467 Troisi R J, Heinold J W, Vokonas P S, Weiss S T. Cigarette smoking, dietary intake, and physical activity: effects on body fat distribution—the Normative Aging Study. Am J Clin Nutr. 1991;53:1104-1111. [pmid: 1850574].
468 Wing R R, Matthews K A, Kuller L H, Meilahn E N, Plantinga P. Waist-to-hip ratio in middle-aged women. Associations with behavioral and psychological factors and with changes in cardiovascular risk factors. Arterioscler Thromb. 1991;11:1250-1257. [pmid: 1911710].
469 Andersen R E, Wadden T A, Bartlett S J, Vogt R A, Weinstock R S. Relation of weight loss to changes in serum lipids and lipoproteins in obese women. Am J Clin Nutr. 1995;62:350-357. [pmid: 7625342].
470 Blonk M C, Jacobs M A, Biesheuvel E H, Weeda-Mannak W L, Heine R J. Influences on weight loss in type 2 diabetic patients: little long-term benefit from group behaviour therapy and exercise training. Diabet Med. 1994;11:449-457. [pmid: 8088122].
471 Neumark-Sztainer D, Kaufmann N A, Berry E M. Physical activity within a community-based weight control program: program evaluation and predictors of success. Public Health Rev. 1995;23:237-251. [pmid: 8559961].
472 Sweeney M E, Hill J O, Heller P A, Baney R, DiGirolamo M. Severe vs moderate energy restriction with and without exercise in the treatment of obesity: efficiency of weight loss. Am J Clin Nutr. 1993;57:127-134. [pmid: 8424379].
473 Wing R R, Epstein L H, Paternostro-Bayles M, Kriska A, Nowalk M P, Gooding W. Exercise in a behavioural weight control programme for obese patients with Type 2 (non-insulin-dependent) diabetes. Diabetologia. 1988;31:902-909. [pmid: 3071485].
474 Kaplan R M, Hartwell S L, Wilson D K, Wallace J P. Effects of diet and exercise interventions on control and quality of life in non-insulin-dependent diabetes mellitus. J Gen Intern Med. 1987;2:220-228. [pmid: 3302144].
475 Leighton R F, Repka F J, Birk T J, et al. The Toledo Exercise and Diet Study. Results at 26 weeks. Arch Intern Med. 1990;150:1016-1020. [pmid: 2184789].
476 Long C G, Simpson C M, Allott E A. Psychological and dietetic counselling combined in the treatment of obesity: a comparative study in a hospital outpatient clinic. Hum Nutr Appl Nutr. 1983;37:94-102. [pmid: 6408031].
477 Wadden T A, Stunkard A J. Controlled trial of very low calorie diet, behavior therapy, and their combination in the treatment of obesity. J Consult Clin Psychol. 1986;54:482-488. [pmid: 3528252].
478 Craighead L W, Stunkard A J, O'Brien R M. Behavior therapy and pharmacotherapy for obesity. Arch Gen Psychiatry. 1981;38:763-768. [pmid: 7247639].
479 Bennett G A. An evaluation of self-instructional training in the treatment of obesity. Addict Behav. 1986;11:125-134. [pmid: 3739798].
480 Bennett G A. Cognitive rehearsal in the treatment of obesity: a comparison against cue avoidance and social pressure. Addict Behav. 1986;11:225-237. [pmid: 3739810].
481 Forster J L, Jeffery R W, Sullivan S, Snell M K. A work-site weight control program using financial incentives collected through payroll deduction. J Occup Med. 1985;27:804-808. [pmid: 4067685].
482 Glasgow R E, Toobert D J, Hampson S E, Brown J E, Lewinsohn P M, Donnelly J. Improving self-care among older patients with type II diabetes: the Sixty Something… Study. Patient Educ Couns. 1992;19:61-74. [pmid: 1298950].
483 Jeffery R W, Hellerstedt W L, Schmid T L. Correspondence programs for smoking cessation and weight control: a comparison of two strategies in the Minnesota Heart Health Program. Health Psychol. 1990;9:585-598. [pmid: 2226387].
484 Lovibond S H, Birrell P C, Langeluddecke P. Changing coronary heart disease risk-factor status: the effects of three behavioral programs. J Behav Med. 1986;9:415-437. [pmid: 3540308].
485 Muchmore D B, Springer J, Miller M. Self-monitoring of blood glucose in overweight type 2 diabetic patients. Acta Diabetol. 1994;31:215-219. [pmid: 7888692].
486 Perri M G, Nezu A M, Patti E T, McCann K L. Effect of length of treatment on weight loss. J Consult Clin Psychol. 1989;57:450-452. [pmid: 2500466].
487 Perri M G, McAllister D A, Gange J J, Jordan R C, McAdoo G, Nezu A M. Effects of four maintenance programs on the long-term management of obesity. J Consult Clin Psychol. 1988;56:529-534. [pmid: 2848874].
488 Rosenthal B, Allen G J, Winter C. Husband involvement in the behavioral treatment of overweight women: initial effects and long-term follow-up. Int J Obes. 1980;4:165-173. [pmid: 7399805].
489 Smith D E, Heckemeyer C M, Kratt P P, Mason D A. Motivational interviewing to improve adherence to a behavioral weight-control program for older obese women with NIDDM. A pilot study. Diabetes Care. 1997;20:52-54. [pmid: 9028693].
490 Uusitupa M, Laitinen J, Siitonen O, Vanninen E, Pyorala K. The maintenance of improved metabolic control after intensified diet therapy in recent type 2 diabetes. Diabetes Res Clin Pract. 1993;19:227-238. [pmid: 8319521].
491 Wadden T A, Berkowitz R I, Vogt R A, Steen S N, Stunkard A J, Foster G D. Lifestyle modification in the pharmacologic treatment of obesity: a pilot investigation of a potential primary care approach. Obes Res. 1997;5:218-226. [pmid: 9192396].
492 Wing R R, Marcus M D, Epstein L H, Jawad A. A “family-based” approach to the treatment of obese Type II diabetic patients. J Consult Clin Psychol. 1991;59:156-162. [pmid: 2002132].
493 Wing R R, Epstein L H, Nowalk M P, Scott N, Koeske R, Hagg S. Does self-monitoring of blood glucose levels improve dietary compliance for obese patients with Type II diabetes?. Am J Med. 1986;81:830-836. [pmid: 3535493].
494 Eldredge K L, Agras W S, Arnow B, et al. The effects of extending cognitive-behavioral therapy for binge eating disorder among initial treatment nonresponders. Int J Eat Disord. 1997;21:347-352. [pmid: 9138046].
495 Agras W S, Berkowitz R I, Arnow B A, et al. Maintenance following a very-low-calorie diet. J Consult Clin Psychol. 1996;64:610-613. [pmid: 8698956].
496 Sobal J, Devin C. Social aspects of obesity. In: Dalton S, ed. Overweight and Weight Management: The Health Professional's Guide To Understanding and Practice. Gaithersburg, MD: Aspen Publishers; 1997:312–331.
497 Brown PJ; Cultural perspectives on the etiology and treatment of obesity. In: Stunkard AJ, Wadden TA, eds. Obesity Theory and Therapy. New York: Raven Press; 1993:179–195.
498 Foster G D, Wadden T A, Vogt R A. Resting energy expenditure in obese African American and Caucasian women. Obes Res. 1997;5:1-8. [pmid: 9061709].
499 Yanovski S Z, Reynolds J C, Boyle A J, Yanovski J A. Resting metabolic rate in African-American and Caucasian girls. Obes Res. 1997;5:321-325. [pmid: 9285838].
500 Albu J B, Murphy L, Frager D H, Johnson J A, Pi-Sunyer F X. Visceral fat and race-dependent health risks in obese nondiabetic premenopausal women. Diabetes. 1997;46:456-462. [pmid: 9032103].
501 Allison D B, Edlen-Nezin L, Clay-Williams G. Obesity among African American women: prevalence, consequences, causes, and developing research. Women's Health. 1997;3:243-274. [pmid: 9426496].
502 Andersson B, Seidell J, Terning K, Bjorntorp P. Influence of menopause on dietary treatment of obesity. J Intern Med. 1990;227:173-181. [pmid: 2313225].
503 Kumanyika S K, Obarzanek E, Stevens V J, Hebert P R, Whelton P K. Weight-loss experience of black and white participants in NHLBI- sponsored clinical trials. Am J Clin Nutr. 1991;53:1631S-1638S. [pmid: 2031498].
504 Wing R R, Anglin K. Effectiveness of a behavioral weight control program for blacks and whites with NIDDM. Diabetes Care. 1996;19:409-413. [pmid: 8732700].
505 Wylie-Rosett J, Wassertheil-Smoller S, Blaufox M D, et al. Trial of antihypertensive intervention and management: greater efficacy with weight reduction than with a sodium-potassium intervention. J Am Diet Assoc. 1993;93:408-415. [pmid: 8454808].
506 Andersen T, Astrup A, Quaade F. Dexfenfluramine as adjuvant to a low-calorie formula diet in the treatment of obesity: a randomized clinical trial. Int J Obes Relat Metab Disord. 1992;16:35-40. [pmid: 1314242].
507 Guy-Grand B, Apfelbaum M, Crepaldi G, Gries A, Lefebvre P, Turner P. International trial of long-term dexfenfluramine in obesity. Lancet. 1989;2:1142-1145. [pmid: 2572857].
508 Finer N. Body weight evolution during dexfenfluramine treatment after initial weight control. Int J Obes Relat Metab Disord. 1992;16(Suppl 3):S25-S29. [pmid: 1338319].
509 Williams R A, Foulsham B M. Weight reduction in osteoarthritis using phentermine. Practitioner. 1981;225:231-232. [pmid: 7022428].
510 Bray G A, Ryan D H, Gordon D, Heidingsfelder S, Cerise F, Wilson K. A double-blind randomized placebo-controlled trial of sibutramine. Obes Res. 1996;4:263-270. [pmid: 8732960].
511 Weintraub M, Ginsberg G, Stein E C, et al. Phenylpropanolamine OROS (Acutrim) vs. placebo in combination with caloric restriction and physician-managed behavior modification. Clin Pharmacol Ther. 1986;39:501-509. [pmid: 3516509].
512 Schteingart D E. Effectiveness of phenylpropanolamine in the management of moderate obesity. Int J Obes Relat Metab Disord. 1992;16:487-493. [pmid: 1323545].
513 Jones SP, Smith IG, Kelly F, Gray JA. Long term weight loss with sibutramine. Int J Obes. 1995;19 (Suppl 2):41 [abstract 071].
514 Weintraub M, Sundaresan P R, Schuster B, et al. Long-term weight control study. IV (weeks 156 to 190). The second double-blind phase. Clin Pharmacol Ther. 1992;51:608-614. [pmid: 1587075].
515 Andersen T, Backer O G, Stokholm K H, Quaade F. Randomized trial of diet and gastroplasty compared with diet alone in morbid obesity. N Engl J Med. 1984;310:352-356. [pmid: 6690963].
516 Andersen T, Backer O G, Astrup A, Quaade F. Horizontal or vertical banded gastroplasty after pretreatment with very-low-calorie formula diet: a randomized trial. Int J Obes. 1987;11:295-304. [pmid: 3312050].
517 Brolin R E, Kenler H A, Gorman J H, Cody R P. Long-limb gastric bypass in the superobese. a prospective randomized study. Ann Surg. 1992;215:387-395. [pmid: 1558421].
518 Naslund I. The size of the gastric outlet and the outcome of surgery for obesity. Acta Chir Scand. 1986;152:205-210. [pmid: 3716740].
519 Hall J C, Watts J M, O'Brien P E, et al. Gastric surgery for morbid obesity. The Adelaide Study. Ann Surg. 1990;211:419-427. [pmid: 2181950].
520 Laws H L, Piantadosi S. Superior gastric reduction procedure for morbid obesity: a prospective, randomized trial. Ann Surg. 1981;193:334-340. [pmid: 7212793].
521 Lechner G W, Callender A K. Subtotal gastric exclusion and gastric partitioning: a randomized prospective comparison of one hundred patients. Surgery. 1981;90:637-644. [pmid: 7025315].
522 Pories W J, Flickinger E G, Meelheim D, Van Rij A M, Thomas F T. The effectiveness of gastric bypass over gastric partition in morbid obesity: consequence of distal gastric and duodenal exclusion. Ann Surg. 1982;196:389-399. [pmid: 7125726].
523 Gastrointestinal surgery for severe obesity. National Institutes of Health Consensus Development Conference Statement. Am J Clin Nutr. 1992;55:615S-619S. [pmid: 1733140].
524 Busetto L, Perini P, Giantin V, et al. Relationship between energy expenditure and visceral fat accumulation in obese women submitted to adjustable silicone gastric banding (ASGB). Int J Obes Relat Metab Disord. 1995;19:227-233. [pmid: 7627245].
525 Zumoff B, Strain G W, Miller L K, et al. Plasma free and non-sex-hormone-binding-globulin-bound testosterone are decreased in obese men in proportion to their degree of obesity. J Clin Endocrinol Metab. 1990;71:929-931. [pmid: 2401718].
526 Gallagher D, Visser M, Sepulveda D, Pierson R N, Harris T, Heymsfield S B. How useful is body mass index for comparison of body fatness across age, sex, and ethnic groups?. Am J Epidemiol. 1996;143:228-239. [pmid: 8561156].
527 Heymsfield SB, Allison DB, Heshka S, Pierson RN Jr. Assessment of human body composition. In: Allison DB, ed. Handbook of Assessment Methods For Eating Behavior and Weight Related Problems: Measures, Theory, and Research. Thousand Oaks, CA: Sage Publications; 1995:515–560.
528 Matz R. Calculating body mass index. Ann Intern Med. 1993;118:232. [pmid: 8417648].
529 Abate N, Garg A, Peshock R M, Stray-Gundersen J, Adams-Huet B, Grundy S M. Relationship of generalized and regional adiposity to insulin sensitivity in men with NIDDM. Diabetes. 1996;45:1684-1693. [pmid: 8922352].
530 Lean M E, Han T S, Morrison C E. Waist circumference as a measure for indicating need for weight management. BMJ. 1995;311:158-161. [pmid: 7613427].
531 Sjostrom L, Kvist H, Cederblad A, Tylen U. Determination of total adipose tissue and body fat in women by computed tomography, 40K, and tritium. Am J Physiol. 1986;250:E736-E745. [pmid: 3717334].
532 Jensen M D, Kanaley J A, Reed J E, Sheedy P F. Measurement of abdominal and visceral fat with computed tomography and dual-energy x-ray absorptiometry. Am J Clin Nutr. 1995;61:274-278. [pmid: 7840063].
533 Despres J P, Moorjani S, Ferland M, et al. Adipose tissue distribution and plasma lipoprotein levels in obese women. Importance of intra-abdominal fat. Arteriosclerosis. 1989;9:203-210. [pmid: 2923576].
534 Pouliot M C, Despres J P, Nadeau A, et al. Visceral obesity in men. Associations with glucose tolerance, plasma insulin, and lipoprotein levels. Diabetes. 1992;41:826-834. [pmid: 1612197].
535 Abate N, Garg A, Peshock R M, Stray-Gundersen J, Grundy S M. Relationships of generalized and regional adiposity to insulin sensitivity in men. J Clin Invest. 1995;96:88-98. [pmid: 7615840].
536 Goodpaster B H, Thaete F L, Thaete J A, Simoneau, Kelley D E. Subcutaneous abdominal fat and thigh muscle composition predict insulin sensitivity independently of visceral fat. Diabetes. 1997;46:1579-1585. [pmid: 9313753].
537 Lemieux S, Prud'homme D, Bouchard C, Tremblay A, Despres J. A single threshold value of waist girth identifies normal-weight and overweight subjects with excess visceral adipose tissue. Am J Clin Nutr. 1996;64:685-693. [pmid: 8901786].
538 National Center for Health Statistics. NHANES III Anthropometric Procedures Video. Washington, DC: U.S. Government Printing Office; 1996. Stock Number 017-022-01335-5.
539 Gordon T, Doyle J T. Weight and mortality in men: the Albany Study. Int J Epidemiol. 1988;17:77-81. [pmid: 3384553].
540 Hamm P, Shekelle R B, Stamler J. Large fluctuations in body weight during young adulthood and 25-year risk of coronary death in men. Am J Epidemiol. 1989;129:312-318. [pmid: 2912043].
541 Lindsted K, Tonstad S, Kuzma J W. Body mass index and patterns of mortality among Seventh-day Adventist men. Int J Obes. 1991;15:397-406. [pmid: 1885263].
542 Norgan N G, Jones P R. The effect of standardising the body mass index for relative sitting height. Int J Obes Relat Metab Disord. 1995;19:206-208. [pmid: 7780498].
543 Conway J M, Yanovski S Z, Avila N A, Hubbard V S. Visceral adipose tissue differences in black and white women. Am J Clin Nutr. 1995;61:765-771. [pmid: 7702017].
544 Potts J, Simmons D. Sex and ethnic group differences in fat distribution in young United Kingdom South Asians and Europids. J Clin Epidemiol. 1994;47:837-841. [pmid: 7730886].
545 Joint National Committee on Detection, Evaluation, and Treatment of High Blood Pressure. The Sixth Report of the Joint National Committee on prevention, detection, evaluation, and treatment of high blood pressure (JNC VI). Arch Intern Med. 1997;157:2413-2446. [pmid: 9385294].
546 American Diabetes Association. ADA Clinical Practice Recommendations 1998. Diabetes Care. 1998;21(Suppl 1):S1-S93. [pmid: 9538961].
547 Fiore MC, Bailey WC, Cohen SF. Smoking Cessation. Clinical Practice Guidelines No. 18. U.S. Department of Health and Human Services, PHS, Agency for Health Care Policy and Research. 1996. (Bookshelf).
548 Paffenbarger R S Jr, Hyde R T, Wing A L, Lee I M, Jung D L, Kampert J B. The association of changes in physical-activity level and other lifestyle characteristics with mortality among men. N Engl J Med. 1993;328:538-545. [pmid: 8426621].
549 NIH Consensus Conference. Triglyceride, high-density lipoprotein, and coronary heart disease. NIH Consensus Development Panel on Triglyceride, High-Density Lipoprotein, and Coronary Heart Disease. JAMA. 1993;269:505-510. [pmid: 8419671].
550 Wadden TA, Wingate BJ. Behavioral assessment and treatment of markedly obese patients. In: Wadden TA, VanItallie TB, eds. Treatment of the Seriously Obese Patient. New York: Guilford Press; 1992:290–330.
551 Stunkard AJ. Talking with patients. In: Stunkard AJ, Wadden TA, eds. Obesity Theory and Therapy. New York: Raven Press; 1993:355–363.
552 Wadden TA, Wingate BJ. Compassionate treatment of the obese individual. In: Brownell KD, Fairburn CG, eds. Eating Disorders and Obesity. New York: Basic Books; 1995:564–571.
553 Foster G D, Wadden T A, Vogt R A, Brewer G. What is a reasonable weight loss? Patients' expectations and evaluations of obesity treatment outcomes. J Consult Clin Psychol. 1997;65:79-85. [pmid: 9103737].
554 Williamson D F, Serdula M K, Anada R F, Levy A, Byers T. Weight loss attempts in adults: goals, duration, and rate of weight loss. Am J Pub Health. 1992;82:1251-1257. [pmid: 1503167].
555 Wing R R, Blair E, Marcus M, Epstein L H H, Harvey J. Year-long weight loss treatment for obese patients with type II diabetes: does including an intermittent very-low-calorie diet improve outcome?. Am J Med. 1994;97:354-362. [pmid: 7942937].
556 VanItallie T B, Yang M -U. Current concepts in nutrition: diets and weight loss. N Engl J Med. 1977;297:1158-1161. [pmid: 917044].
557 Yang M, VanItallie TB. Effect of energy restriction on body composition and nitrogen balance in obese individuals. In: Wadden TA, VanItallie TB, eds. Treatment of the Seriously Obese Patient. New York: Guilford Press; 1992:83–106.
558 National Task Force on the Prevention and Treatment of Obesity, National Institutes of Health. Very low-calorie diets. JAME. 1993;270:967-974. [pmid: 8345648].
559 Tremblay A, Buemann B, Theriault G, Bouchard C. Body fatness in active individuals reporting low lipid and alcohol intake. Eur J Clin Nutr. 1995;49:824-831. [pmid: 8557020].
560 Gruchow H W, Sobocinski K A, Barboriak J J, Scheller J G. Alcohol consumption, nutrient intake and relative body weight among US adults. Am J Clin Nutr. 1985;42:289-295. [pmid: 4025199].
561 de Castro J M, Orozco S. Moderate alcohol intake and spontaneous eating patterns of humans: evidence of unregulated supplementation. Am J Clin Nutr. 1990;52:246-253. [pmid: 2375290].
562 Veenstra J, Schenkel J A, van Erp-Baart A M, et al. Alcohol consumption in relation to food intake and smoking habits in the Dutch National Food Consumption Survey. Eur J Clin Nutr. 1993;47:482-489. [pmid: 8404783].
563 Tremblay A, Wouters E, Wenker M, St-Pierre S, Bouchard C, Despres J P. Alcohol and a high-fat diet: a combination favoring overfeeding. Am J Clin Nutr. 1995;62:639-644. [pmid: 7661127].
564 Tremblay A, St-Pierre S. The hyperphagic effect of a high-fat diet and alcohol intake persists after control for energy density. Am J Clin Nutr. 1996;63:479-482. [pmid: 8599309].
565 Poppitt S D, Eckhardt J W, McGonagle J, Murgatroyd P R, Prentice A M. Short-term effects of alcohol consumption on appetite and energy intake. Physiol Behav. 1996;60:1063-1070. [pmid: 8884934].
566 Foltin R W, Kelly T H, Fischman M W. Ethanol as an energy source in humans: comparison with dextrose-containing beverages. Appetite. 1993;20:95-110. [pmid: 8507071].
567 Butrum R R, Clifford C K, Lanza E. NCI dietary guidelines: rationale. Am J Clin Nutr. 1988;48(3 Suppl):888-895. [pmid: 3046317].
568 United States. Public Health Service. Office of the Surgeon General. Nutrition and Health: A Report of the Surgeon General. Washington, DC: Government Printing Office; 1988:192.
569 NIH Consensus Conference. Optimal calcium intake. NIH Consensus Development Panel on Optimal Calcium Intake. JAMA. 1994;272:1942-1948. [pmid: 7990248].
570 Wadden TA, Letizia KA. Predictors of attrition and weight loss in patients treated by moderate and severe caloric restriction. In: Wadden TA, VanItallie TB, eds. Treatment of the Seriously Obese Patient. New York: Guilford Press; 1992:383–410.
571 Foreyt J P, Goodrick G K. Factors common to successful therapy for the obese patient. Med Sci Sports Exerc. 1991;23:292-297. [pmid: 2020266].
572 Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion. Surgeon General's Report on Physical Activity and Health. Atlanta, GA: CDC; 1996.
573 Blair S N, Kampert J B, Kohl H W III, et al. Influences of cardiorespiratory fitness and other precursors on cardiovascular disease and all-cause mortality in men and women. JAMA. 1996;276:205-210. [pmid: 8667564].
574 Kohl H W, Gordon N F, Villegas J A, Blair S N. Cardiorespiratory fitness, glycemic status, and mortality risk in men. Diabetes Care. 1992;15:184-192. [pmid: 1547675].
575 Tremblay A, Nadeau A, Despres J P, St-Jean L, Theriault G, Bouchard C. Long-term exercise training with constant energy intake. 2: effect on glucose metabolism and resting energy expenditure. Int J Obes. 1990;14:75-84. [pmid: 2179148].
576 Wing R R, Marcus M D, Blair E H, Burton L R. Psychological responses of obese Type II diabetic subjects to very low-calorie diet. Diabetes Care. 1991;14:596-599. [pmid: 1914801].
577 Pate R R, Pratt M, Blair S N, et al. Physical activity and public health. A recommendation from the Centers for Disease Control and Prevention and the American College of Sports Medicine. JAMA. 1995;273:402-407. [pmid: 7823386].
578 NIH Consensus Conference. Physical Activity and Cardiovascular Health. JAMA. 1996;276:241-246. [pmid: 8667571].
579 Wadden TA, Foster GD. Behavioral assessment and treatment of markedly obese patients. In: Wadden TA, VanItallie TB, eds. Treatment of the Seriously Obese Patient. New York: Guilford Press; 1992:290–330.
580 Wadden TA. The treatment of obesity. In: Stunkard AJ, Wadden TA, eds. Obesity: Theory and Therapy. New York: Raven Press; 1993:197–217.
581 Wilson GT, Fairborn CG. Treatments of eating disorders. In: Nathan PE, Gorman JM, eds. A Guide To Treatments That Work. New York: Oxford University Press; 1997:501–530.
582 Schlundt D G, Hill J O, Pope-Cordle J, Arnold D, Virts K L, Katahn M. Randomized evaluation of a low fat ad libitum carbohydrate diet for weight reduction. Int J Obes Relat Metab Disord. 1993;17:623-629. [pmid: 8281220].
583 Tremblay A, Almeras N, Boer J, Kranenbarg E K, Despres J P. Diet composition and postexercise energy balance. Am J Clin Nutr. 1994;59:975-979. [pmid: 8172103].
584 King N A, Blundell J E. High-fat foods overcome the energy expenditure induced by high-intensity cycling or running. Eur J Clin Nutr. 1995;49:114-123. [pmid: 7743984].
585 NIH Technology Assessment Conference Panel. Methods for voluntary weight loss and control. Ann Intern Med. 1992;116:942-949. [pmid: 1580453].
586 Atanassoff P G, Weiss B M, Schmid E R, Tornic M. Pulmonary hypertension and dexfenfluramine. Lancet. 1992;339:436. [pmid: 1346703].
587 Brenot F, Herve P, Petitpretz P, Parent F, Duroux P, Simonneau G. Primary pulmonary hypertension and fenfluramine use. Br Heart J. 1993;70:537-541. [pmid: 8280518].
588 Voelker R. Obesity drug renews toxicity debate. JAMA. 1994;272:1087-1088. [pmid: 7933303].
589 Food and Drug Administration. Draft Guidance Clinical Evaluation of Weight Control Drug. Rockville, MD: FDA; 1996.
590 Bray G A. Use and abuse of appetite-suppressant drugs in the treatment of obesity. Ann Intern Med. 1993;119:707-713. [pmid: 8363202].
591 Galloway S M, Farquhar D L, Munro J F. The current status of antiobesity drugs. Postgrad Med J. 1984;60(Suppl 3):19-26. [pmid: 6393107].
592 National Task Force on the Prevention and Treatment of Obesity. Long-term pharmacotherapy in the management of obesity. JAMA. 1996;276:1907-1915. [pmid: 8968018].
593 Weintraub M, Bray G A. Drug treatment of obesity. Med Clin North Am. 1989;73:237-249. [pmid: 2643006].
594 MacDonald K G Jr, Long S D, Swanson M S, et al. The gastric bypass operation reduces the progression and mortality of non-insulin-dependent diabetes mellitus. J Gastrointest Surg. 1997;1:213-220. [pmid: 9834350].
595 Pories W J Swanson M S MacDonald K G JrWho would have thought it? An operation proves to be the most effective therapy for adult-onset diabetes mellitus Ann Surg 1995 222 339–350; discussion 350–352. 7677463
596 Harris T B, Savage P J, Tell G S, Haan M, Kumanyika S, Lynch J C. Carrying the burden of cardiovascular risk in old age: associations of weight and weight change with prevalent cardiovascular disease, risk factors, and health status in the Cardiovascular Health Study. Am J Clin Nutr. 1997;66:837-844. [pmid: 9322558].
597 Tayback M, Kumanyika S, Chee E. Body weight as a risk factor in the elderly. Arch Intern Med. 1990;150:1065-1072. [pmid: 2331187].
598 Galanos A N, Pieper C F, Cornoni-Huntley J C, Bales C W, Fillenbaum G G. Nutrition and function: is there a relationship between body mass index and the functional capabilities of community-dwelling elderly?. J Am Geriatr Soc. 1994;42:368-373. [pmid: 8144820].
599 Keil J E, Gazes P C, Sutherland S E, Rust P F, Branch L G, Tyroler H A. Predictors of physical disability in elderly blacks and whites of the Charleston Heart Study. J Clin Epidemiol. 1989;42:521-529. [pmid: 2525608].
600 Launer L J, Harris T, Rumpel C, Madans J. Body mass index, weight change, and risk of mobility disability in middle-aged and older women. The epidemiologic follow-up study of NHANES I. JAMA. 1994;271:1093-1098. [pmid: 8151851].
601 Willett W C. Weight loss in the elderly: cause or effect of poor health?. Am J Clin Nutr. 1997;66:737-738. [pmid: 9322545].
602 Galanis D J, Harris T, Sharp D S, Petrovitch H. Relative weight, weight change, and risk of coronary heart disease in the Honolulu Heart Program. Am J Epidemiol. 1998;147:379-386. [pmid: 9508105].
603 Chaturvedi N, Fuller J H. Mortality risk by body weight and weight change in people with NIDDM. The WHO Multinational Study of Vascular Disease in Diabetes. Diabetes Care. 1995;18:766-774. [pmid: 7555501].
604 Iribarren C, Sharp D S, Burchfiel C M, Petrovitch H. Association of weight loss and weight fluctuation with mortality among Japanese-American men. N Engl J Med. 1995;333:686-692. [pmid: 7637745].
605 Pamuk E R, Williamson D F, Madans J, Serdula M K, Kleinman J C, Byers T. Weight loss and mortality in a national cohort of adults, 1971-1987. Am J Epidemiol. 1992;136:686-697. [pmid: 1442735].
606 Rumpel C, Harris T B, Madans J. Modification of the relationship between the Quetelet index and mortality by weight-loss history among older women. Ann Epidemiol. 1993;3:343-350. [pmid: 8275209].
607 Wallace J I, Schwartz R S, LaCroix A Z, Uhlmann R F, Pearlman R A. Involuntary weight loss in older outpatients: incidence and clinical significance. J Am Geriatr Soc. 1995;43:329-337. [pmid: 7706619].
608 Ensrud K E, Cauley J, Lipschutz R, Cummings S R. Weight change and fractures in older women. Study of Osteoporotic Fractures Research Group. Arch Intern Med. 1997;157:857-863. [pmid: 9129545].
609 Langlois J A, Harris T, Looker A C, Madans J. Weight change between age 50 years and old age is associated with risk of hip fracture in white women aged 67 years and older. Arch Intern Med. 1996;156:989-994. [pmid: 8624179].
610 Shapses SA, Heymsfield SB, Ricci TA. Voluntary weight reduction increases bone turnover and loss. In: Burckhardt P, Heaney R, Dawson-Hughes B, eds. Nutritional Aspects of Osteoporosis. New York: Springer-Verlag; 1998.
611 Michel B A, Lane N E, Bloch D A, Jones H H, Fries J F. Effect of changes in weight-bearing exercise on lumbar bone mass after age fifty. Ann Med. 1991;23:397-401. [pmid: 1930935].
612 Marcus R, Drinkwater B, Dalsky G, et al. Osteoporosis and exercise in women. Med Sci Sports Exerc. 1992;24(Suppl 6):S301-S307. [pmid: 1625555].
613 Gerace T A, Hollis J, Ockene J K, Svendsen K. Smoking cessation and change in diastolic blood pressure, body weight, and plasma lipids. MRFIT Research Group. Prev Med. 1991;20:602-620. [pmid: 1758841].
614 Klesges R C, Meyers A W, Klesges L M, La Vasque M E. Smoking, body weight, and their effects on smoking behavior: a comprehensive review of the literature. Psychol Bull. 1989;106:204-230. [pmid: 2678202].
615 Williamson D F, Madans J, Anda R F, Kleinman J C, Giovino G A, Byers T. Smoking cessation and severity of weight gain in a national cohort. N Engl J Med. 1991;324:739-745. [pmid: 1997840].
616 Pirie P L, Murray D M, Luepker R V. Gender differences in cigarette smoking and quitting in a cohort of young adults. Am J Public Health. 1991;81:324-327. [pmid: 1994740].
617 Pomerleau C S, Kurth C L. Willingness of female smokers to tolerate postcessation weight gain. J Subst Abuse. 1996;8:371-378. [pmid: 8934441].
618 Hall S M, Tunstall C D, Vila K L, Duffy J. Weight gain prevention and smoking cessation: cautionary findings. Am J Public Health. 1992;82:799-803. [pmid: 1585959].
619 Spring B, Pingotore R, Kesler K. Cigarette smoking and body weight: strategies to minimize weight gain after smoking cessation. Int J Obes. 1992;16:S19-S23.
620 Perkins K A, Epstein L H, Marks B L, Stiller R L, Jacob R G. The effect of nicotine on energy expenditure during light physical activity. N Engl J Med. 1989;320:898-903. [pmid: 2927460].
621 Stamford B A, Matter S, Fell R D, Papanek P. Effects of smoking cessation on weight gain, metabolic rate, caloric consumption, and blood lipids. Am J Clin Nutr. 1986;43:486-494. [pmid: 3962901].
622 Gilbert R M, Pope M A. Early effects of quitting smoking. Psychopharmacology (Berl). 1982;78:121-127. [pmid: 6817366].
623 Spring B, Wurtman J, Gleason R, Wurtman R, Kessler K. Weight gain and withdrawal symptoms after smoking cessation: a preventive intervention using d-fenfluramine. Health Psychol. 1991;10:216-223. [pmid: 1879394].
624 Gross J, Stitzer M L, Maldonado J. Nicotine replacement: effects of postcessation weight gain. J Consult Clin Psychol. 1989;57:87-92. [pmid: 2925978].
625 Klesges R C, Klesges L M, Meyers A W, Klem M L, Isbell T. The effects of phenylpropanolamine on dietary intake, physical activity, and body weight after smoking cessation. Clin Pharmacol Ther. 1990;47:747-754. [pmid: 2357868].
626 Hurt R D, Sachs D P L, Clover E D, et al. A comparison of sustained-release bupropion and placebo for smoking cessation. N Engl J Med. 1997;337:1195-1202. [pmid: 9337378].
627 Perri M G, Lauer J B, Yancey D Z, et al. Effects of peer support and therapist contact on long-term weight loss. J Consult Clin Psychol. 1987;55:615-617. [pmid: 3624623].
628 Broussard B A, Johnson A, Himes J H, et al. Prevalence of obesity in American Indians and Alaska Natives. Am J Clin Nutr. 1991;53:1535S-1542S. [pmid: 2031484].
629 Hodge A M, Dowse G K, Toelupe P, Collins V R, Imo T, Zimmet P Z. Dramatic increase in the prevalence of obesity in western Samoa over the 13 year period 1978-1991. Int J Obes Relat Metab Disord. 1994;18:419-428. [pmid: 8081434].
630 Health Care Financing Administration. Medicare Current Beneficiary Survey: 1991. Percentage of medicare beneficiaries who are overweight, by race, gender, and education. Published Data. 1991.
631 Avila P, Hovell M F. Physical activity training for weight loss in Latinas: a controlled trial. Int J Obes Relat Metab Disord. 1994;18:476-482. [pmid: 7920873].
632 Cousins J H, Rubovits D S, Dunn J K, Reeves R S, Ramirez A G, Foreyt J P. Family versus individually oriented intervention for weight loss in Mexican-American women. Public Health Rep. 1992;107:549-555. [pmid: 1410236].
633 Daniel E L. A multi-intervention weight management program for low-income rural women. J Am Diet Assoc. 1989;89:1310-1311. [pmid: 2768749].
634 Domel S B, Alford B B, Cattlett H N, Gench B E. Weight control for black women. J Am Diet Assoc. 1992;92:346-348. [pmid: 1552136].
635 Domel S B, Alford B B, Cattlett H N, Rodriguez M L, Gench B E. A pilot weight control program for Hispanic women. J Am Diet Assoc. 1992;92:1270-1271. [pmid: 1401669].
636 Fox R A, Haniotes H, Rotatori A. A streamlined weight loss program for moderately retarded adults in a sheltered workshop setting. Appl Res Ment Retard. 1984;5:69-79. [pmid: 6721482].
637 Heath G W, Wilson R H, Smith J, Leonard B E. Community-based exercise and weight control: diabetes risk reduction and glycemic control in Zuni Indians. Am J Clin Nutr. 1991;53:1642S-1646S. [pmid: 2031500].
638 Kanders B S, Ullmann-Joy P, Foreyt J P, et al. The black American lifestyle intervention (BALI): the design of a weight loss program for working-class African-American women. J Am Diet Assoc. 1994;94:310-312. [pmid: 8120297].
639 Kumanyika SK, Brancato J, Brewer A, et al. Interventions in the Trials of Nonpharmacologic Intervention in the Elderly. Effective approaches to weight and sodium reduction among older adults. Circulation. 1996;94:I-690.
640 Kumanyika S K, Charleston J B. Lose weight and win: a church-based weight loss program for blood pressure control among black women. Patient Educ Couns. 1992;19:19-32. [pmid: 1298945].
641 Lasco R A, Curry R H, Dickson V J, Powers J, Menes S, Merritt R K. Participation rates, weight loss, and blood pressure changes among obese women in a nutrition-exercise program. Public Health Rep. 1989;104:640-646. [pmid: 2511599].
642 McNabb W, Quinn M, Kerver J, Cook S, Karrison T. The PATHWAYS church-based weight loss program for urban African-American women at risk for diabetes. Diabetes Care. 1997;20:1518-1523. [pmid: 9314627].
643 McNabb W L, Quinn M T, Rosing L. Weight loss program for inner-city black women with non-insulin-dependent diabetes mellitus: Pathways. J Am Diet Assoc. 1993;93:75-77. [pmid: 8417099].
644 Mount M A, Kendrick O W, Draughon M, Stitt K R, Head D, Mount R. Group participation as a method to achieve weight loss and blood glucose control. J Nutr Educ. 1991;23:25-29.
645 Mulrow C, Bailey S, Sonksen P H, Slavin B. Evaluation of an audiovisual diabetes education program: Negative results of a randomized trial of patients with non-insulin-dependent diabetes mellitus. J Gen Intern Med. 1987;2:215-219. [pmid: 2441013].
646 Pleas J. Long-term effects of a lifestyle-change obesity treatment program with minorities. J Natl Med Assoc. 1988;80:747-752. [pmid: 3404555].
647 Shintani T T, Hughes C K, Beckham S, O'Connor H K. Obesity and cardiovascular risk intervention through an ad libitum feeding of traditional Hawaiian diet. Am J Clin Nutr. 1991;53:1647S-1651S. [pmid: 2031501].
648 Sullivan J, Carter J P. A nutrition-physical fitness intervention program for low-income black parents. J Natl Med Assoc. 1985;77:39-43. [pmid: 3968714].
649 Gleadhill I C, Schwartz A R, Schubert N, Wise R A, Permutt S, Smith P L. Upper airway collapsibility in snorers and in patients with obstructive hypopnea and apnea. Am Rev Respir Dis. 1991;143:1300-1303. [pmid: 2048817].
650 Gold A R, Schwartz A R, Wise R A, Smith P L. Pulmonary function and respiratory chemosensitivity in moderately obese patients with sleep apnea. Chest. 1993;103:1325-1329. [pmid: 8486005].
651 Block A J, Boysen P G, Wynne J W, Hunt L A. Sleep apnea, hypopnea, and oxygen desaturation in normal subjects. A strong male predominance. N Engl J Med. 1979;300:513-517. [pmid: 216912].
652 Guilleminault C, Dement WC. Sleep Apnea Syndromes. Conference on Sleep Apnea Syndromes. New York: Liss; 1978.
653 Schmidt-Nowara W W. Cardiovascular consequences of sleep apnea. Prog Clin Biol Res. 1990;345:377-385. [pmid: 2198598].
654 Norton P G, Dunn E V. Snoring as a risk factor for disease: an epidemiological survey. Br Med J (Clin Res Ed). 1985;291:630-632. [pmid: 3928056].
655 Jennum P, Hein H O, Suadicani P, Gyntelberg F. Cardiovascular risk factors in snorers. A cross-sectional study of 3,323 men aged 54 to 74 years: the Copenhagen Male Study. Chest. 1992;102:1371-1376. [pmid: 1424854].
656 Stradling J R, Crosby J H. Predictors and prevalence of obstructive sleep apnoea and snoring in 1001 middle aged men. Thorax. 1991;46:85-90. [pmid: 2014507].
657 Guilleminault C, Quera-Salva M A, Partinen M, Jamieson A. Women and the obstructive sleep apnea syndrome. Chest. 1988;93:104-109. [pmid: 3335138].
658 Connolly H M, Crary J L, McGoon M D, et al. Valvular heart disease associated with Fenfluramine—Phentermine. N Engl J Med. 1997;337:581-588. [pmid: 9271479].
659 Hedner J. Vascular function in OSA. Sleep. 1996;19(10 Suppl):S213-S217. [pmid: 9085514].
660 Tofler G H, Brezinski D, Schafer A I, et al. Concurrent morning increase in platelet aggregability and the risk of myocardial infarction and sudden cardiac death. N Engl J Med. 1987;316:1514-1518. [pmid: 3587281].
661 He J, Kryger M H, Zorick F J, Conway W, Roth T. Mortality and apnea index in obstructive sleep apnea. Experience in 385 male patients. Chest. 1988;94:9-14. [pmid: 3289839].
662 Partinen M, Jamieson A, Guilleminault C. Long-term outcome for obstructive sleep apnea syndrome patients. Mortality. Chest. 1988;94:1200-1204. [pmid: 3191760].
663 Harman E M, Wynne J W, Block A J. The effect of weight loss on sleep-disordered breathing and oxygen desaturation in morbidly obese men. Chest. 1982;82:291-294. [pmid: 7105855].
664 Charuzi I, Ovnat A, Peiser J, Saltz H, Weitzman S, Lavie P. The effect of surgical weight reduction on sleep quality in obesity-related sleep apnea syndrome. Surgery. 1985;97:535-538. [pmid: 3992478].
665 Peiser J, Lavie P, Ovnat A, Charuzi I. Sleep apnea syndrome in the morbidly obese as an indication for weight reduction surgery. Ann Surg. 1984;199:112-115. [pmid: 6691724].
666 Sugerman H J, Fairman R P, Baron P L, Kwentus J A. Gastric surgery for respiratory insufficiency of obesity. Chest. 1986;90:81-86. [pmid: 3720390].
667 Rubinstein I, Colapinto N, Rotstein L E, Brown I G, Hoffstein V. Improvement in upper airway function after weight loss in patients with obstructive sleep apnea. Am Rev Respir Dis. 1988;138:1192-1195. [pmid: 3202479].
668 Smith P L, Gold A R, Meyers D A, Haponik E F, Bleecker E R. Weight loss in mildly to moderately obese patients with obstructive sleep apnea. Ann Intern Med. 1985;103:850-855. [pmid: 3933396].
669 Aubert-Tulkens G, Culee C, Rodenstein D O. Cure of sleep apnea syndrome after long-term nasal continuous positive airway pressure therapy and weight loss. Sleep. 1989;12:216-222. [pmid: 2662343].
670 Pasquali R, Colella P, Cirignotta F, et al. Treatment of obese patients with obstructive sleep apnea syndrome (OSAS): effect of weight loss and interference of otorhinolaryngoiatric pathology. Int J Obes. 1990;14:207-217. [pmid: 2341227].
671 Suratt P M, McTier R F, Findley L J, Pohl S L, Wilhoit S C. Effect of very low-calorie diets with weight loss on obstructive sleep apnea. Am J Clin Nutr. 1992;56:182S-184S. [pmid: 1615880].
672 Schwartz A R, Gold A R, Schubert N, et al. Effect of weight loss on upper airway collapsibility in obstructive sleep apnea. Am Rev Respir Dis. 1991;144:494-498. [pmid: 1892285].
673 American Thoracic Society. Indications and standards for use of nasal continuous positive airway pressure (CPAP) in sleep apnea syndromes. Am J Resp Crit Care Med. 1994;150:1738-1745. [pmid: 7952642].
674 Andersson B, Elam M, Wallin B G, Bjorntorp P, Andersson O K. Effect of energy-restricted diet on sympathetic muscle nerve activity in obese women. Hypertension. 1991;18:783-789. [pmid: 1743759].
675 Andersson O K, Fagerberg B, Hedner T. Haemodynamic adjustment to weight reduction—separate effects of energy versus salt restriction. J Hypertens Suppl. 1983;1:35-37. [pmid: 6599493].
676 Collins R W, Anderson J W. Medication cost savings associated with weight loss for obese non-insulin-dependent diabetic men and women. Prev Med. 1995;24:369-374. [pmid: 7479627].
677 Darne B, Nivarong M, Tugaye A, et al. Hypocaloric diet and antihypertensive drug treatment. A randomized controlled clinical trial. Blood Press. 1993;2:130-135. [pmid: 8180725].
678 Gillett P A, Eisenman P A. The effect of intensity controlled aerobic dance exercise on aerobic capacity of middle-aged, overweight women. Res Nurs Health. 1987;10:383-390. [pmid: 3423310].
679 Treatment of Mild Hypertension Research Group. The treatment of mild hypertension study. A randomized, placebo-controlled trial of a nutritional-hygienic regimen along with various drug monotherapies. Arch Intern Med. 1991;151:1413-1423. [pmid: 2064494].
680 Jeffery R W, Gillum R, Gerber W M, Jacobs D, Elmer P J, Prineas R J. Weight and sodium reduction for the prevention of hypertension: a comparison of group treatment and individual counseling. Am J Public Health. 1983;73:691-693. [pmid: 6846677].
681 Kanaley J A, Andresen-Reid M L, Oenning L, Kottke B A, Jensen M D. Differential health benefits of weight loss in upper-body and lower-body obese women. Am J Clin Nutr. 1993;57:20-26. [pmid: 8416660].
682 Kumanyika S K. The impact of obesity on hypertension management in African Americans. J Health Care Poor Underserved. 1997;8:352-364. [pmid: 9253227].
683 Mellies M J, Vitale C, Jandacek R J, Lamkin G E, Glueck C J. The substitution of sucrose polyester for dietary fat in obese, hypercholesterolemic outpatients. Am J Clin Nutr. 1985;41:1-12. [pmid: 3966411].
684 Page R C, Harnden K E, Cook J T, Turner R C. Can lifestyles of subjects with impaired glucose tolerance be changed? A feasibility study. Diabet Med. 1992;9:562-566. [pmid: 1643806].
685 Ready A E, Drinkwater D T, Ducas J, Fitzpatrick D W, Brereton D G, Oades S C. Walking program reduces elevated cholesterol in women postmenopause. Can J Cardiol. 1995;11:905-912. [pmid: 7489529].
686 Rigaud D, Ryttig K R, Angel L A, Apfelbaum M. Overweight treated with energy restriction and a dietary fibre supplement: a 6-month randomized, double-blind, placebo-controlled trial. Int J Obes. 1990;14:763-769. [pmid: 2172178].
687 Rissanen A, Pietinen P, Siljamaki-Ojansuu U, Piirainen H, Reissel P. Treatment of hypertension in obese patients: efficacy and feasibility of weight and salt reduction programs. Acta Med Scand. 1985;218:149-156. [pmid: 4061119].
688 Ryttig K R, Rossner S. Weight maintenance after a very low calorie diet (VLCD) weight reduction period and the effects of VLCD supplementation. A prospective, randomized, comparative, controlled long-term trial. J Intern Med. 1995;238:299-306. [pmid: 7595165].
689 Singh R B, Niaz M A, Bishnoi I, Singh U, Begum R, Rastogi S S. Effect of low energy diet and weight loss on major risk factors, central obesity and associated disturbances in patients with essential hypertension. J Hum Hypertens. 1995;9:355-362. [pmid: 7623373].
690 Singh R B, Niaz M A, Ghosh S. Effect on central obesity and associated disturbances of low-energy, fruit- and vegetable-enriched prudent diet in north Indians. Postgrad Med J. 1994;70:895-900. [pmid: 7870637].
691 Singh R B, Rastogi S S, Sircar A R, Mehta P J, Sharma K K. Dietary strategies for risk-factor modification to prevent cardiovascular diseases. Nutrition. 1991;7:210-214. [pmid: 1666320].
692 Stokholm K H, Nielsen P E, Quaade F. Correlation between initial blood pressure and blood pressure decrease after weight loss: a study in patients with jejunoileal bypass versus medical treatment for morbid obesity. Int J Obes. 1982;6:307-312. [pmid: 7118361].
693 Walker K Z, O'Dea K, Nicholson G C, Muir J G. Dietary composition, body weight, and NIDDM. Comparison of high-fiber, high-carbohydrate, and modified-fat diets. Diabetes Care. 1995;18:401-403. [pmid: 7555486].
694 Wing R R, Jeffery R W, Burton L R, Thorson C, Kuller L H, Folsom A R. Change in waist-hip ratio with weight loss and its association with change in cardiovascular risk factors. Am J Clin Nutr. 1992;55:1086-1092. [pmid: 1595579].
695 Astrup A, Breum L, Toubro S, Hein P, Quaade F. The effect and safety of an ephedrine/caffeine compound compared to ephedrine, caffeine and placebo in obese subjects on an energy-restricted diet. A double blind trial. Int J Obes Relat Metab Disord. 1992;16:269-277. [pmid: 1318281].
696 Connacher A A, Jung R T, Mitchell P E. Weight loss in obese subjects on a restricted diet given BRL 26830A, a new atypical beta adrenoceptor agonist. Br Med J (Clin Res Ed). 1988;296:1217-1220. [pmid: 2898268].
697 Daly P A, Krieger D R, Dulloo A G, Young J B, Landsberg L. Ephedrine, caffeine and aspirin: safety and efficacy for treatment of human obesity. Int J Obes Relat Metab Disord. 1993;17(Suppl 1):S73-S78. [pmid: 8384187].
698 Marin P, Holmang S, Jonsson L, et al. The effects of testosterone treatment on body composition and metabolism in middle-aged obese men. Int J Obes Relat Metab Disord. 1992;16:991-997. [pmid: 1335979].
699 Rasmussen M H, Andersen T, Breum L, Gotzsche P C, Hilsted J. Cimetidine suspension as adjuvant to energy restricted diet in treating obesity. BMJ. 1993;306:1093-1096. [pmid: 8388286].
700 Coon P J, Bleecker E R, Drinkwater D T, Meyers D A, Goldberg A P. Effects of body composition and exercise capacity on glucose tolerance, insulin, and lipoprotein lipids in healthy older men: a cross-sectional and longitudinal intervention study. Metabolism. 1989;38:1201-1209. [pmid: 2687639].
701 Franz M J, Monk A, Barry B, et al. Effectiveness of medical nutrition therapy provided by dietitians in the management of non-insulin-dependent diabetes mellitus: a randomized, controlled clinical trial. J Am Diet Assoc. 1995;95:1009-1017. [pmid: 7657902].
702 Milne R M, Mann J I, Chisholm A W, Williams S M. Long-term comparison of three dietary prescriptions in the treatment of NIDDM. Diabetes Care. 1994;17:74-80. [pmid: 8112194].
703 Ready A E, Fitzpatrick D W, Boreskie S L, Hrycaiko D W. The response of obese females to low impact exercise and diet counselling. J Sports Med Phys Fitness. 1991;31:587-595. [pmid: 1806739].
704 Singman H S, Berman S N, Cowell C, Maslansky E, Archer M. The Anti-Coronary Club: 1957 to 1972. Am J Clin Nutr. 1980;33:1183-1191. [pmid: 7386407].
705 Suter E, Marti B, Gutzwiller F. Jogging or walking—comparison of health effects. Ann Epidemiol. 1994;4:375-381. [pmid: 7981845].
706 Viddal K O. Intestinal bypass. A randomized, prospective clinical study of end-to-side and end-to-end jejunoileal bypass. Scand J Gastroenterol. 1983;18:627-634. [pmid: 6675183].
707 Williams P T, Wood P D, Haskell W L, Vranizan K. The effects of running mileage and duration on plasma lipoprotein levels. JAMA. 1982;247:2674-2679. [pmid: 6952022].
708 Wing R R, Marcus M D, Salata R, Epstein L H, Miaskiewicz S, Blair E H. Effects of a very low-calorie diet on long-term glycemic control in obese Type 2 diabetic subjects. Arch Intern Med. 1991;151:1334-1340. [pmid: 2064484].
709 Wing R R, Blair E, Marcus M, Epstein L H, Harvey J. Year-long weight loss treatment for obese patients with type II diabetes: does including an intermittent very low-calorie diet improve outcome?. Am J Med. 1994;97:354-362. [pmid: 7942937].
710 Drent M L, Larsson I, William-Olsson T, et al. Orlistat (Ro 18-0647), a lipase inhibitor, in the treatment of human obesity: a multiple dose study. Int J Obes Relat Metab Disord. 1995;19:221-226. [pmid: 7627244].
711 Pedrinola F, Sztejnsznajd C, Lima N, Halpern A, Medeiros-Neto G. The addition of dexfenfluramine to fluoxetine in the treatment of obesity: a randomized clinical trial. Obes Res. 1996;4:549-554. [pmid: 8946439].
712 Connolly V M, Gallagher A, Kesson C M. A study of fluoxetine in obese elderly patients with type 2 diabetes. Diabet Med. 1995;12:416-418. [pmid: 7648804].
713 Alpert M A, Terry B E, Lambert C R, et al. Factors influencing left ventricular systolic function in nonhypertensive morbidly obese patients, and effect of weight loss induced by gastroplasty. Am J Cardiol. 1993;71:733-737. [pmid: 8447274].
714 Cairella G, Cairella M, Marchini G. Effect of dietary fiber on weight correction after modified fasting. Eur J Clin Nutr. 1995;49(Suppl 3):S325-S327. [pmid: 8549559].
715 Foster G D, Wadden T A, Peterson F J, Letizia K A, Bartlett S J, Conill A M. A controlled comparison of three very low-calorie diets: effects on weight, body composition, and symptoms. Am J Clin Nutr. 1992;55:811-817. [pmid: 1550063].
716 Hakala P. Weight reduction programmes at a rehabilitation centre and a health centre based on group counselling and individual support: short- and long-term follow-up study. Int J Obes Relat Metab Disord. 1994;18:483-489. [pmid: 7920874].
717 Han T S, Richmond P, Avenell A, Lean M E. Waist circumference reduction and cardiovascular benefits during weight loss in women. Int J Obes Relat Metab Disord. 1997;21:127-134. [pmid: 9043967].
718 Lean M E, Han T S, Prvan T, Richmond P R, Avenell A. Weight loss with high and low carbohydrate 1200 kcal diets in free living women. Eur J Clin Nutr. 1997;51:243-248. [pmid: 9104574].
719 Miura J, Arai K, Tsukahara S, Ohno M, Ikeda Y. The long-term effectiveness of combined therapy by behavior modification and very low-calorie diet: 2 years followup. Int J Obes. 1989;13(Suppl 2):73-77. [pmid: 2613431].
720 Walker K Z, O'Dea K, Johnson L, et al. Body fat distribution and non-insulin-dependent diabetes: comparison of a fiber-rich, high-carbohydrate, low-fat (23%) diet and a 35% fat diet high in monounsaturated fat. Am J Clin Nutr. 1996;63:254-260. [pmid: 8561068].
721 Foster G D, Wadden T A, Feurer I D, et al. Controlled trial of the metabolic effects of a very low-calorie diet: short-and long-term effects. Am J Clin Nutr. 1990;51:167-172. [pmid: 2407096].
722 Golay A, Allaz A F, Morel Y, de Tonnac N, Tankova S, Reaven G. Similar weight loss with low- or high-carbohydrate diets. Am J Clin Nutr. 1996;63:174-178. [pmid: 8561057].
723 Rossner S, Flaten H. VLCD versus LCD in long-term treatment of obesity. Int J Obes Relat Metab Disord. 1997;21:22-26. [pmid: 9023596].
724 Jarrett R J, Keen H, Murrells T. Changes in blood pressure and body weight over ten years in men selected for glucose intolerance. J Epidemiol Community Health. 1987;41:145-151. [pmid: 3655634].
725 Gwinup G. Weight loss without dietary restriction: efficacy of different forms of aerobic exercise. Am J Sports Med. 1987;15:275-279. [pmid: 3618879].
726 Hespel P, Lijnen P, Van Hoof R, et al. Effects of physical endurance training on the plasma renin-angiotensin-aldosterone system in normal man. J Endocrinol. 1988;116:443-449. [pmid: 3280723].
727 King A C, Taylor C B, Haskell W L, DeBusk R F. Influence of regular aerobic exercise on psychological health: a randomized, controlled trial of healthy middle-aged adults. Health Psychol. 1989;8:305-324. [pmid: 2767021].
728 Karvetti R L, Knuts L R. Effects of comprehensive rehabilitation on weight reduction in myocardial infarction patients. Scand J Rehabil Med. 1983;15:11-16. [pmid: 6828828].
729 Liao Y, Emidy L A, Gosch F C, Stamler R, Stamler J. Cardiovascular responses to exercise of participants in a trial on the primary prevention of hypertension. J Hypertens. 1987;5:317-321. [pmid: 3611779].
730 Darga L L, Carroll-Michals L, Botsford S J, Lucas C P. Fluoxetine's effect on weight loss in obese subjects. Am J Clin Nutr. 1991;54:321-325. [pmid: 1858696].
731 Elmer P J, Grimm R Jr, Laing B, et al. Lifestyle intervention: results of the Treatment of Mild Hypertension Study (TOMHS). Prev Med. 1995;24:378-388. [pmid: 7479629].
732 Foreyt J P, Ramirez A G, Cousins J H. Cuidando El Corazon—a weight-reduction intervention for Mexican Americans. Am J Clin Nutr. 1991;53:1639S-1641S. [pmid: 2031499].
733 Hogan R B, Johnston J H, Long B W, et al. A double-blind, randomized, sham-controlled trial of the gastric bubble for obesity. Gastrointest Endosc. 1989;35:381-385. [pmid: 2792672].
734 Marcus M D, Wing R R, Ewing L, Kern E, McDermott M, Gooding W. A double-blind, placebo-controlled trial of fluoxetine plus behavior modification in the treatment of obese binge-eaters and non-binge-eaters. Am J Psychiatry. 1990;147:876-881. [pmid: 2192563].
735 Stamler J, Briefel R R, Milas C, Grandits G A, Caggiula A W. Relation of changes in dietary lipids and weight, trial years 1–6, to changes in blood lipids in the special intervention and usual care groups in the Multiple Risk Factor Intervention Trial. Am J Clin Nutr. 1997;65:272S-288S. [pmid: 8988942].
736 Wing R R, Shoemaker M, Marcus M D, McDermott M, Gooding W. Variables associated with weight loss and improvements in glycemic control in type II diabetic patients in behavioral weight control programs. Int J Obes. 1990;14:495-503. [pmid: 2401586].
737 DeLucia J L, Kalodner C R, Horan J J. The effect of two nutritional software programs used as adjuncts to the behavioral treatment of obesity. J Subst Abuse. 1988-1989;1:203-208. [pmid: 2980870].
738 DeLucia J L, Kalodner C R. An individualized cognitive intervention: does it increase the efficacy of behavioral interventions for obesity?. Addict Behav. 1990;15:473-479. [pmid: 2248121].
739 Heitzmann C A, Kaplan R M, Wilson D K, Sandler J. Sex differences in weight loss among adults with type II diabetes mellitus. J Behav Med. 1987;10:197-211. [pmid: 3612778].
740 Jeffery R W, Forster J L, French S A, et al. The Healthy Worker Project: a work-site intervention for weight control and smoking cessation. Am J Public Health. 1993;83:395-401. [pmid: 8438979].
741 Jeffery R W, Forster J L, Snell M K. Promoting weight control at the worksite: a pilot program of self-motivation using payroll-based incentives. Prev Med. 1985;14:187-194. [pmid: 4048081].
742 Jones S E, Owens H M, Bennett G A. Does behaviour therapy work for dietitians? An experimental evaluation of the effects of three procedures in a weight reduction clinic. Hum Nutr Appl Nutr. 1986;40:272-281. [pmid: 3759500].
743 Kalodner C R, DeLucia J L. The individual and combined effects of cognitive therapy and nutrition education as additions to a behavior modification program for weight loss. Addict Behav. 1991;16:255-263. [pmid: 1776542].
744 Schwartz S H, Inbar-Saban N. Value self-confrontation as a method to aid in weight loss. J Pers Soc Psychol. 1988;54:396-404. [pmid: 3361417].
745 Breum L, Astrup A, Andersen T, et al. The effect of long-term dexfenfluramine treatment on 24-hour energy expenditure in man. A double-blind placebo controlled study. Int J Obes. 1990;14:613-621. [pmid: 2228396].
746 Finer N, Finer S, Naoumova R P. Drug therapy after very-low-calorie diets. Am J Clin Nutr. 1992;56:195S-198S. [pmid: 1615883].
747 Pasquali R, Cesari M P, Melchionda N, Stefanini C, Raitano A, Labo G. Does ephedrine promote weight loss in low-energy-adapted obese women?. Int J Obes. 1987;11:163-168. [pmid: 3301709].
748 Weintraub M, Hasday J D, Mushlin A I, Lockwood D H. A double-blind clinical trial in weight control. Use of fenfluramine and phentermine alone and in combination. Arch Intern Med. 1984;144:1143-1148. [pmid: 6375610].
749 Weintraub M, Sundaresan P R, Schuster B, et al. Long-term weight control study. II (weeks 34 to 104). An open-label study of continuous fenfluramine plus phentermine versus targeted intermittent medication as adjuncts to behavior modification, caloric restriction, and exercise. Clin Pharmacol Ther. 1992;51:595-601. [pmid: 1587073].
750 Bitsch M, Skrumsager B K. Femoxetine in the treatment of obese patients in general practice. A randomized group comparative study with placebo. Int J Obes. 1987;11:183-190. [pmid: 3301710].
751 Fernandez-Soto M L, Gonzalez-Jimenez A, Barredo-Acedo F, Luna del Castillo J D, Escobar-Jimenez F. Comparison of fluoxetine and placebo in the treatment of obesity. Ann Nutr Metab. 1995;39:159-163. [pmid: 7486842].
752 Goldstein D J, Rampey A H Jr, Enas G G, Potvin J H, Fludzinski L A, Levine L R. Fluoxetine: a randomized clinical trial in the treatment of obesity. Int J Obes Relat Metab Disord. 1994;18:129-135. [pmid: 8186809].
753 Cook R F, Howard A N, Mills I H. Low-dose mianserin as adjuvant therapy in obese patients treated by a very-low-calorie diet. Int J Obes. 1981;5:267-272. [pmid: 7024156].
754 Steel J M, Munro J F, Duncan L J. A comparative trial of different regimens of fenfluramine and phentermine in obesity. Practitioner. 1973;211:232-236. [pmid: 4580610].
755 Sax L. Yohimbine does not affect fat distribution in men. Int J Obes. 1991;15:561-565. [pmid: 1960007].
756 Benjamin S B, Maher K A, Cattau E L Jr, et al. Double-blind controlled trial of the Garren-Edwards gastric bubble: an adjunctive treatment for exogenous obesity. Gastroenterology. 1988;95:581-588. [pmid: 3294079].
757 Mathus-Vliegen E M, Tytgat G N, Veldhuyzen-Offermans E A. Intragastric balloon in the treatment of super-morbid obesity. Double-blind, sham-controlled, crossover evaluation of 500-milliliter balloon. Gastroenterology. 1990;99:362-369. [pmid: 2194894].
758 Bray G A, Gray D S. Obesity. Part I—Pathogenesis. West J Med. 1988;149:429-441. [pmid: 3067447].
759 Centers for Disease Control and Prevention. Number and percentage of children and adolescents who were overweight by gender and race/ethnicity: United States NHANES III, 1988-1994. Morb Mortal Wkly Rep. 1997.
760 National Center of Health Statistics. Center of Disease Prevention and Control, National Health and Nutrition Examination Survey, Phase III. Prevalence of overweight in U.S. adults, by race/ethnicity, gender, and education, 1988-1991.
761 Centers for Disease Control. Cardiac valvulopathy associated with exposure to Fenfluramine or Dexfenfluramine: U.S. Department of Health and Human Services interim public health recommendation, November 1997. MMWR Morb Mortal Wkly Rep. 1997;46:1061–1065.
762 American Psychiatric Association. Task Force on DSM-IV, Diagnostic and Statistical Manual of Mental Disorders : DSM-IV. 4th ed. Washington, DC: The Association; 1994.
763 Landin K, Stigendal L, Eriksson E, et al. Abdominal obesity is associated with an impaired fibrinolytic activity and elevated plasminogen activator inhibitor-I. Metabolism. 1990;39:1044-1048. [pmid: 2215252].
764 Reisin E, Frohlich E D, Messerli F H, Dreslinski G R, et al. Cardiovascular changes after weight reduction in obesity hypertension. Ann Intern Med. 1983;98:315-319. [pmid: 6338789].
765 Tuck M I, Sowers J, Dornfield L, et al. The effect of weight reduction on blood pressure plasma renin activity and plasma aldosterone level in obese patients. N Engl J Med. 1981;304:930-933. [pmid: 7010165].
766 Rocchini A P, Key J, Bondie D, et al. The effect of weight loss on the sensitivity of blood pressure to sodium in obese adolescents. N Engl J Med. 1989;321:580-585. [pmid: 2668763].
767 Landsberg L, Krieger D R. Obesity, metabolism, and the sympathetic nervous system. Am J Hypertens. 1989;2:125S-132S. [pmid: 2647103].
768 Jacobs D B, Sowers J R, et al. Effects of weight reduction on cellular cation metabolism and vascular resistance. Hypertension. 1993;21:308-314. [pmid: 8478040].
769 Frohlich E D, Apstein C, Chobanian A V, et al. The heart in hypertension. N Engl J Med. 1992;327:998-1008. [pmid: 1518549].