# List of Abbreviations

AAFP: American Academy of Family Physicians
ADA: American Diabetes Association
AHCPR: Agency for Health Care Policy and Research
AHI: Apnea and Hypopnea Index
ATP II: Second Report of the Expert Panel on the Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel II)
BED: Binge Eating Disorder
BMI^*^: Body Mass Index
BN: Bulimia Nervosa
CAD: Coronary Artery Disease
CARDIA: Coronary Artery Risk Development in Young Adults
CDC: Centers for Disease Control and Prevention
CHD^*^: Coronary Heart Disease
CHF: Congestive Heart Failure
CPAP: Continuous Positive Airway Pressure
CRSS: Critical Review Status Sheet
CT^*^: Computed Tomography
CVD: Cardiovascular Disease
DEXA^*^: Dual-Energy X-ray Absorpiometry
DNA: Deoxyribonucleic Acid
FDA: Food and Drug Administration
HDL^*^: High-Density Lipoprotein
HHANES: Hispanic Health and Nutrition Examination Survey
HMO: Health Maintenance Organization
IGT: Impaired Glucose Tolerance
INDEX trial: International Dexfenfluramine Study
INTERSALT: International study of SALT
IOM: Institute of Medicine
JNC VI: Sixth Report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure
LCD^*^: Low-Calorie Diets
LDL^*^: Low-Density Lipoprotein
MEDLINE: MEDLARS (Medical Literature Analysis and Retrieval System) On-Line
MeSH: Medical Subject Headings
MMPI: Minnesota Multiphasic Personality Inventory
MRI^*^: Magnetic Resonance Imaging
NAASO: North American Association for the Study of Obesity
NCEP: National Cholesterol Education Program
NCHS: National Center for Health Statistics (CDC)
NHANES^*^: National Health and Nutrition Examination Survey
NHBPEP: National High Blood Pressure Education Program
NHES: National Health Examination Survey
NHIS: National Health Interview Survey
NHLBI: National Heart, Lung, and Blood Institute
NIDDK: National Institute of Diabetes and Digestive and Kidney Diseases
NIH: National Institutes of Health
NLM: National Library of Medicine
RCTs^*^: Randomized Controlled Trials
RDI: Respiratory Disturbance Index
SOS: Swedish Obesity Study
SSRIs: Selective Serotonin Reuptake Inhibitors
TAIM: Trial of Antihypertensive Interventions and Management
TOHP I: Trials of Hypertension Prevention (Phase 1)
TOHP II: Trials of Hypertension Prevention (Phase 2)
TONE: Trial of Nonpharmacologic Interventions in the Elderly
VLCD^*^: Very Low-Calorie Diets
VLDL^*^: Very Low-Density Lipoprotein
VO_2_ max^*^: Oxygen Consumption
WHR^*^: Waist-to-Hip Ratio

* Terms defined in the glossary.