# Resource List

For additional information on overweight and obesity, and related conditions or diseases, you may wish to contact the professional organizations listed below.

The Federal consumer health information gateway, healthfinder, (www.healthfinder.gov) offers convenient access to these and many other resources.

American Dietetic Association

216 West Jackson Boulevard

Chicago, IL 60606-6995

(800) 877-1600

FAX: (312) 899-1979 http://www.eatright.org

- Eat Right America program
- List of nutrition resources
- Find a dietitian, 1-800-366-1655

American College of Sports Medicine

P.O. Box 1440

Indianapolis, IN 46206-1440

(317) 637-9200

FAX: (317) 634-7817 http://www.acsm.org

- Health and Fitness Summit and Exposition
- National Coalition for Promoting Physical Activity
- Public information

National Heart, Lung, and Blood Institute

Education Programs Information Center

P.O. Box 30105

Bethesda, MD 20824-0105

(301) 251-1222

FAX: (301) 251-1223 http://www.nhlbi.nih.gov/nhlbi/nhlbi.htm

(general NHLBI site)

- Online publications on blood pressure, overweight, cholesterol, heart disease, sleep disorders, and asthma

National Institute of Diabetes and Digestive and Kidney Diseases

31 Center Drive, MSC-2560

Building 31, Room 9A-04

Bethesda, MD 20892-2560

(301) 496-3583

FAX: (301) 496-7422 http://www.niddk.nih.gov

- Many online patient information publications on diabetes
- Many online publications on nutrition and obesity
- WIN — the Weight-Control Information Network 1-800-WIN-8098

The Weight-Control Information Network

National Institute of Diabetes and Digestive and Kidney Diseases

1 WIN WAY

Bethesda, MD 20892-3665

(301) 570-2177

FAX: (301) 570-2186

1-800-WIN-8098

National Digestive Diseases Information Clearinghouse (NIDDK)

2 Information Way

Bethesda, MD 20892-3570

(301) 654-3810

FAX: (301) 907-8906

National Kidney and Urologic Diseases Information Clearinghouse (NIDDK)

3 Information Way

Bethesda, MD 20892-3580

(301) 654-4415

FAX: (301) 907-8906

National Diabetes Information Clearinghouse (NIDDK)

1 Information Way

Bethesda, MD 20892-3560

(301) 654-3327

FAX: (301) 907-8906

American Diabetes Association

1660 Duke Street

Alexandria, VA 22314

1-800 DIABETES http://www.diabetes.org

- List of publications

American Cancer Society

Atlanta, GA

1-800-ACS-2345 http://www.cancer.org

- Dietary guidelines online
- List of publications

National Cancer Institute

Office of Cancer Communications

9000 Rockville Pike

Building 31, Room 10A-24

Bethesda, MD 20892

(800) 4-CANCER (800-422-6237) http://www.nci.nih.gov

- Many publications online, including those on nutrition and cancer

National Eating Disorders Organization

6655 South Yale Avenue

Tulsa, OK 74136

(918) 481-4044

FAX: (918) 481-4076 http://www.laureate.com/aboutned.html

- Publications list
- Online descriptive information

Eating Disorders Awareness and Prevention, Inc.

603 Stewart Street, Suite 803

Seattle, WA 98101

(206) 382-3587 http://members.aol.com/edapinc/home.html

- Online descriptive information
- Publications list

American Anorexia/Bulimia Association, Inc.

165 West 46th Street #1108

New York, NY 10036

(212) 575-6200 http://members.aol.com/amanbu/index.html

- Online descriptive information

National Association of Anorexia Nervosa and Associated Disorders

P.O.Box 7

Highland Park, IL 60035

(847) 831-3438

FAX: (847) 433-4632 http://www.medpatients.com/Health%20 Resources/NAANAD.htm

American Heart Association

7272 Greenville Avenue

Dallas, TX 75231-4596

(214) 706-1220

FAX: (214) 706-1341

1-800-AHA-USA1 (800-242-8721) http://www.americanheart.org

- Publications list
- Online information
- Stroke Connection 1-800-553-6321

Hypertension Network, Inc. http://www.bloodpressure.com

- Online information
- Weekly research updates

National Institute of Neurological Disorders and Stroke

P.O. Box 5801

Bethesda, MD 20824

(301) 496-5751 http://www.ninds.nih.gov

- Online publications on stroke
- Publications list

National Center on Sleep Disorders Research

National Heart, Lung, and Blood Institute

Two Rockledge Centre, Suite 7024

6701 Rockledge Drive, MSC 7920

Bethesda, MD 20892-7920

(301) 435-0199

FAX: (301) 480-3451

American Sleep Disorders Association

1610 14th Street NW, Suite 300

Rochester, MN 55901

(507) 287-6006

Fax: (507) 287-6008 http://www.asda.org

- List of member centers
- Online descriptive information

The Sleep Medicine Home Page http://www.users.cloud9.net/~thorpy

- List of internet resources
- List of centers
- Online descriptive information

National Mental Health Association

1201 Prince Street

Alexandria, VA 22314-2971

(703) 684-7722

Fax: (703) 684-5968

800/969-NMHA Information Center http://www.nmha.org

North American Association for the Study of Obesity (NAASO)

8630 Fenton Street

Suite 412

Silver Spring, MD 20910

(301) 563-6526

Fax: (301) 587-2365 http://www.naaso.org