# Practical Dietary Therapy Information

## A.1 Shopping—What To Look For

a. Low-Calorie Shopping List
b. Low-Calorie, Lower-Fat Alternatives
c. Fat-Free Versus Regular—Calorie Comparisons
d. Good Sources of Calcium

## A.2 Food Preparation—What To Do

- Low-Calorie, Low-Fat Cooking/Serving Methods

## A.3 Dining Out—How To Choose

a. General Tips for Healthy Dining Out
b. Tips for Healthy Multicultural Dining Out

## A.4 Sample Reduced-Calorie Menus

a. Traditional American Cuisine—Reduced Calorie
b. Asian-American Cuisine—Reduced Calorie
c. Southern Cuisine—Reduced Calorie
d. Mexican-American Cuisine—Reduced Calorie
e. Lacto-Ovo Vegetarian Cuisine—Reduced Calorie

## VI.A.1 Shopping—What To Look For

Figure VI.A.1 Low-Calorie Shopping List

### Low-Calorie Shopping List

We live in a fast-moving world. To reduce the time you spend in the kitchen you can improve your organization by using a shopping list and keeping a well-stocked kitchen. Shop for quick low-fat food items, and fill your kitchen cupboards with a supply of low-calorie basics.

Read labels as you shop. Pay attention to the serving size and the servings per container. All labels list total calories in a serving size of the products. Compare the total calories in the product you choose with others like it; choose the one that is lowest in calories. Below is a label that identifies important information.

[image]

### VI.A.1.b Low-Calorie, Lower-Fat Alternatives

These low-calorie alternatives provide new ideas for old favorites. When making a food choice, remember to consider vitamins and minerals. Some foods provide most of their calories from sugar and fat but give you few if any vitamins and minerals.

This guide is not meant to be an exhaustive list. We stress reading labels to find out just how many calories are in the specific products you decide to buy.

Figure VI.A.1.b Food Comparison

### VI.A.1.c Fat-Free Versus Regular—Calorie Comparison

A calorie is a calorie is a calorie…whether it comes from fat or carbohydrate. Anything eaten in excess can lead to weight gain. You can lose weight by eating less calories and by increasing your physical activity. Reducing the amount of fat and saturated fat that you eat is one easy way to limit your overall calorie intake. However, eating fat-free or reduced-fat foods isn't always the answer to weight loss. For example, if you eat twice as many fat-free cookies as regular cookies you may not have reduced your overall calorie intake. The following list of foods and their fat-free varieties will show you that just because a product is fat-free, it doesn't mean that it is “calorie-free.” And, calories do count!

Table VI.A.1.c

Fat-Free or Reduced Fat | | Regular
| Calories | | Calorie
Reduced-Fat Peanut Butter, 2 tablespoons | 190 | Regular Peanut Butter, 2 tablespoons | 190
Cookies: | | Cookies:
Reduced-Fat Chocolate Chip Cookie, 1 cookie | 128 | Regular Chocolate Chip Cookie, 1 cookie | 136
Fat-Free Fig Cookie, 1 cookie | 70 | Fig Cookie, 1 cookie | 50
Ice Cream: | | Ice Cream:
Premium Nonfat Frozen Yogurt ½ cup | 190 | Regular Ice Cream ½ cup | 180
Premium Reduced-Fat Ice Cream ½ cup | 190 | Regular Ice Cream ½ cup | 180
Fat-Free Caramel Topping, 2 tablespoons | 130 | Butterscotch Caramel Topping, 2 tablespoons | 130
Reduced-Fat Granola Cereal, ¼ cup | 110 | Granola Cereal, ¼ cup | 130
Reduced-Fat Croissant Roll, 1 roll | 110 | Regular Croissant Roll, 1 roll | 130
Baked Tortilla Chips, 1 ounce | 110 | Regular Tortilla Chips, 1 ounce | 130
Reduced-Fat Breakfast Bar, 1 bar | 140 | Breakfast Bar, 1 bar | 130

### VI.A.1.d Good Sources of Calcium

Calcium is not just for growing children. It is an important mineral that adults also need to keep their bones and teeth strong and their muscles functioning. Many people do not eat enough calcium everyday. The following is a list of good sources of calcium and tips on how to include more calcium in your diet everyday.

Table VI.A.1.d

Source | Calcium (milligrams)
Milk (1 cup)
Whole | 300
2% reduced-fat | 300
1%* low-fat | 300
Fat free* | 300
Yogurt* (1 cup)
Plain, low-fat | 415
Flavored, low-fat | 315
Plain, fat free | 315
Cheese (1 ounce)
Reduced-fat Cheddar* | 120
American | 175
Swiss Cheese | 270
Mozzarella, part-skim | 185
Cottage Cheese (½ cup)
2% reduced-fat | 75
Calcium fortified cottage cheese | 300
Ice Cream
Regular, ½ cup | 90
Low-fat, ½ cup | 100
Frozen Yogurt
Low-fat, ½ cup | 100
Beans, dried cooked, 1 cup | 90
Salmon, with bones, 3 ounces | 205
Tofu, processed with calcium sulfate, ½ cup | 435
Spinach, fresh cooked | 244
Turnip Greens, fresh cooked, 1 cup | 100
Kale, fresh cooked | 94
Broccoli, fresh cooked | 75
Waffle, 7" diameter | 180
Pancakes, (2) 4" diameter | 115
Pizza, with vegetables, ¼ 12" pie | 180

* Low-fat and nonfat varieties of foods are still good sources of calcium.

Calcium Requirements

Age | Women | Men
19–24 | 1,200 mg | 1,200 mg
25–50 | 1,000 mg | 800 mg

#### Tips for Fitting in Calcium

- Eat cereal with fat-free milk. Try adding fresh fruit.
- Drink an extra glass of milk every day; try calcium-fortified milk.
- Spread calcium-fortified cottage cheese^*^ on crackers or bagel. Add fresh fruit.
  * Read food labels for products with added calcium
- Drink calcium-fortified orange juice.^*^
- Blend a yogurt smoothie with low-fat or fat-free yogurt and milk, and fresh or frozen fruit.
- Make instant pudding with low-fat or fat-free milk.
- Choose frozen yogurt for dessert instead of cake or cookies.
- Add a slice of low-fat or fat-free cheese to sandwiches.
- Substitute calcium fortified tofu in stir-fries for chicken, shrimp, or beef.
- Sauté greens (kale, bok choy, collard greens) in cooking spray and lemon juice and herbs.

## VI.A.2 Food Preparation—What to Do

### Low-Calorie, Low-Fat Cooking/ Serving Methods

Cooking low-calorie, low-fat dishes may not take a long time, but best intentions can be lost with the addition of butter or other added fats at the table. It is important to learn how certain ingredients can add unwanted calories and fat to low-fat dishes—making them no longer lower in calories and lower in fat! The following list provides examples of lower fat-cooking methods and tips on how to serve your low-fat dishes.

#### Low-Fat Cooking Methods

These cooking methods tend to be lower in fat:

- Bake
- Broil
- Microwave
- Roast—for vegetables and/or chicken without skin
- Steam
- Lightly stir-fry or sauté in cooking spray, small amounts of vegetable oil, or reduced sodium broth
- Grill seafood, chicken or vegetables

#### How To Save Calories and Fat

Look at the following examples for how to save calories and fat when preparing and serving foods. You might be surprised at how easy it is!

- Two tablespoons of butter on a baked potato can add an extra 200 calories and 22 grams of fat! However, ¼ cup salsa only adds 18 calories and no fat!
- Two tablespoons of regular clear Italian salad dressing will add an extra 136 calories and 14 grams of fat. Reduced fat Italian dressing only adds 30 calories and 2 grams of fat!

#### Try These Low-Fat Flavorings—added during preparation or at the table

- Herbs—oregano, basil, cilantro, thyme, parsley, sage, or rosemary
- Spices—cinnamon, nutmeg, pepper, or paprika
- Reduced-fat or fat-free salad dressing
- Mustard
- Catsup
- Fat-free or reduced-fat mayonnaise
- Fat-free or reduced-fat sour cream
- Fat-free or reduced-fat yogurt
- Reduced sodium soy sauce
- Salsa
- Lemon or lime juice
- Vinegar
- Horseradish
- Fresh ginger
- Sprinkle of butter flavor (not made with real butter)
- Red pepper flakes
- Sprinkle of parmesan cheese (stronger flavor than most cheese)
- Sodium-free salt substitute
- Jelly or fruit preserves on toast or bagels

## VI.A.3 Dining Out—How to Choose

### General Tips for Healthy Dining Out

Whether or not you're trying to lose weight, you can eat healthy when dining out or bringing in food, if you know how. The following tips will help you move toward healthier eating as you limit your calories, as well as fat, saturated fat, cholesterol, and sodium when eating out.

#### You Are the Customer -

- Ask for what you want! Most restaurants will honor your requests.
- Ask questions! Don't be intimidated by the menu - your server will be able to tell you how foods are prepared or suggest substitutions on the menu.
- If you wish to reduce portion sizes - try ordering appetizers as your main meal.

General Tips: Limiting your calories and fat can be easy as long as you know what to order. Try asking these questions when you call ahead or before you order. Ask the restaurant “Do you or would you on request…”:

- Serve margarine (rather than butter) with the meal?
- Serve fat-free (skim) milk rather than whole milk or cream?
- Use less oil when cooking?
- Trim visible fat off poultry or meat?
- Leave all butter, gravy, or sauces off a side dish or entree?
- Serve salad dressing on the side?
- Accommodate special requests if made in advance by telephone or in person?
- Above all else, don't get discouraged. There are usually several healthy choices to choose from at most restaurants.

#### Reading the Menu -

- Choose lower-calorie, low-fat cooking methods. Look for terms like steamed, in its own juice (au jus), garden fresh, broiled, baked, roasted, poached, tomato juice, dry boiled (in wine or lemon juice), and lightly sautéed or stir-fried.
- Be aware of foods high in calories, fat, and saturated fat. Watch out for terms like butter sauce, fried, crispy, creamed, in cream or cheese sauce, au gratin, au fromage, escalloped, parmesan, hollandaise, bernaise, marinated (in oil), stewed, basted, sautéed, stir-fried, casserole, hash, prime, pot pie and pastry crust.

#### Specific Tips for Healthy Choices

#### Breakfast

- Fresh fruit or small glass of citrus juice
- Whole grain bread, bagel or English muffin with jelly or honey
- Whole grain cereal with low-fat (1%) or fatfree milk
- Oatmeal with fat-free milk topped with fruit
- Omelet made with egg whites or egg substitute
- Multigrain pancakes without butter on top
- Nonfat yogurt (try adding cereal or fresh fruit)

#### Beverages

- Water with lemon
- Flavored sparkling water (noncaloric)
- Juice spritzer (half fruit juice and half sparkling water)
- Iced tea
- Tomato juice (reduced sodium)

#### Bread

Most bread and breadsticks are low in calories and low in fat. The calories add up when you add butter, margarine, or olive oil to the bread. Also, eating a lot of bread in addition to your meal will fill you up with extra unwanted calories and not leave enough room for fruits and vegetables.

#### Appetizers

- Steamed seafood
- Shrimp^*^ cocktail (limit cocktail sauce - it's high in sodium)
  * If you are on a cholesterol-lowering diet, eat shrimp and other shellfish in moderation.
- Melons or fresh fruit
- Bean soups
- Salad with reduced fat dressing (or add lemon juice or vinegar)

#### Entree

- Poultry, fish, shellfish and vegetable dishes are healthy choices
- Pasta with red sauce or with vegetables (primavera)
- Look for terms like baked, broiled, steamed, poached, lightly sautéed or stir-fried
- Ask for sauces and dressings on the side
- Limit the amount of butter, margarine, and salt you use at the table

#### Salads/Salad Bars

- Fresh greens, lettuce and spinach
- Fresh vegetables - tomato, mushroom, carrots, cucumber, peppers, onion, radishes, and broccoli
- Beans, chick peas and kidney beans
- Skip the nonvegetable choices: deli meats, bacon, egg, cheese, croutons
- Choose lower-calorie, reduced-fat or fat-free dressing, lemon juice, or vinegar

#### Side Dish

- Plain vegetables and starches (rice, potato, noodles) make good additions to meals and can also be combined for a lower-calorie alternative to higher-calorie entrees
- Ask for side dishes without butter or margarine
- Ask for mustard, salsa or low-fat yogurt instead of sour cream or butter

#### Dessert/Coffee

- Fresh fruit
- Nonfat frozen yogurt
- Sherbet or fruit sorbet (these are usually fat free, but check the calorie content)
- Try sharing a dessert
- Ask for low-fat milk for your coffee (instead of cream or half-'n-half)

### VI.A.3.b Tips for Healthy Multicultural Dining Out

If you're dining out or bringing in, it is easy to find healthy foods. Knowing about American food terms, as well as other ethnic cuisines can help make your dining experience healthy and enjoyable! The following list includes healthy food choices (lower in calories and fat) and terms to look for when making your selection.

#### Chinese

#### Choose More Often…

- Steamed
- Jum (poached)
- Chu (boiled)
- Kow (roasted)
- Shu (barbecued)
- Hoison sauce with assorted Chinese vegetables: broccoli, mushroom, onion, cabbage, snow peas, scallions, bamboo shoots, water chestnuts, asparagus
- Oyster sauce (made from seafood)
- Lightly stir-fried in mild sauce
- Cooked in light wine sauce
- Hot and spicy tomato sauce
- Sweet and sour sauce
- Hot mustard sauce
- Reduced sodium soy sauce
- Dishes without MSG added
- Garnished with spinach or broccoli
- Fresh fish filets, shrimp, scallops
- Chicken, without skin
- Lean beef
- Bean curd (tofu)
- Moo Shu vegetable, chicken or shrimp
- Steamed rice
- Lychee fruit

#### French

#### Choose More Often…

- Dinner salad with vinegar or lemon juice dressing (or other reduced fat dressing)
- Crusty bread without butter
- Fresh fish, shrimp, scallops, steamed mussels (without sauces)
- Chicken breast, without skin
- Rice and noodles without cream or added butter or other fat
- Fresh fruit for dessert

#### Italian

#### Choose More Often…

- Lightly sautéed with onions
- Shallots
- Peppers and mushrooms
- Artichoke hearts
- Sun-dried tomatoes
- Red sauces - spicy marinara sauce (arrabiata), marinara sauce or cacciatore
- Light red sauce or light red or white wine sauce
- Light mushroom sauce
- Red clam sauce
- Primavera (no cream sauce)
- Lemon sauce
- Capers
- Herbs and spices - garlic and oregano
- Crushed tomatoes and spices
- Florentine (spinach)
- Grilled (often fish or vegetables)
- Piccata (lemon)
- Manzanne (eggplant)

#### Middle Eastern

#### Choose More Often…

- Lemon dressing, lemon juice
- Blended or seasoned with Middle Eastern spices
- Herbs and spices
- Mashed chickpeas
- Fava beans
- Smoked eggplant
- With tomatoes, onions, green peppers and cucumbers
- Spiced ground meat
- Special garlic sauce
- Basted with tomato sauce
- Garlic
- Chopped parsley and/or onion
- Couscous (grain)
- Rice or bulgur (cracked wheat)
- Stuffed with rice and imported spices
- Grilled on a skewer
- Marinated and barbecued
- Baked
- Charbroiled or charcoal broiled
- Fresh fruit

#### Japanese

#### Choose More Often…

- House salad with fresh ginger and cellophane (clear rice) noodles
- Rice
- Nabemono
- Chicken, fish or shrimp teriyaki, broiled in sauce
- Menrui or soba noodles, often used in soups
- Yakimono (broiled)
- Tofu or bean curd
- Grilled vegetables

#### Indian

#### Choose More Often…

- Tikka (pan roasted)
- Cooked with or marinated in yogurt
- Cooked with green vegetables, onions, tomatoes, peppers, and mushrooms
- With spinach (saag)
- Baked leavened bread
- Masala
- Tandoori
- Paneer
- Cooked with curry, marinated in spices
- Lentils, chick beans, garbanzo beans, beans
- Garnished with dried fruits
- Chickpeas (garbanzo) and potatoes
- Basmati rice (pullao)
- Matta (peas)
- Chicken or shrimp kebab

#### Mexican

#### Choose More Often…

- Shredded spicy chicken
- Rice and black beans
- Rice
- Ceviche (fish marinated in lime juice and mixed with spices)
- Served with salsa (hot red tomato sauce)
- Served with salsa verde (green chili sauce)
- Covered with enchilada sauce
- Topped with shredded lettuce, diced tomatoes and onions
- Served with or wrapped in a corn or wheat flour (soft) tortilla
- Grilled
- Marinated
- Picante sauce
- Simmered with chili vegetarian tomato sauce

#### Thai

#### Choose More Often…

- Barbecue, sautéed, broiled boiled or steamed, braised, marinated
- Charbroiled
- Basil sauce, basil or sweet basil leaves
- Lime sauce or lime juice
- Chili sauce or crushed dried chili flakes
- Thai spices
- Served in hollowed-out pineapple
- Fish sauce
- Hot sauce
- Napa, bamboo shoots, black mushrooms, ginger, garlic
- Bed of mixed vegetables
- Scallions, onions

#### Steakhouses

#### Choose More Often…

- Lean broiled beef (no more than 6 ounces) - London broil, filet mignon, round and flank steaks
- Baked potato without added butter, margarine or sour cream. Try low-fat yogurt or mustard.
- Green salad with reduced fat dressing
- Steamed vegetables without added butter or margarine. Try lemon juice and herbs.
- Seafood dishes (usually indicated as “surf” on menus)

#### Fast Food

- Grilled chicken breast sandwich without mayonnaise
- Single hamburger without cheese
- Grilled chicken salad with reduced-fat dressing
- Garden salad with reduced-fat dressing
- Low-fat or nonfat yogurt
- Fat-free muffin
- Cereal with low-fat milk

#### Deli/Sandwich Shop

#### Choose More Often…

- Fresh sliced vegetables in pita bread with low-fat dressing, yogurt or mustard
- Cup of bean soup (lentil, minestrone)
- Turkey breast sandwich with mustard, lettuce, tomato
- Fresh fruit

Sample Reduced-Calorie Menus

| | Total CHO | Total Fat | Sodium | SFA | Cholesterol | Protein
| Calories | % kcal | % kcal | (mg) | % kcal | (mg) | % kcal
Traditional Cuisine
1,600 | 1,613 | 55 | 29 | 1,341 | 8 | 142 | 19
1,200 | 1,247 | 58 | 26 | 1,043 | 7 | 96 | 19
Asian-American Cuisine
1,600 | 1,609 | 56 | 27 | 1,296 | 8 | 148 | 20
1,200 | 1,220 | 55 | 27 | 1,043 | 8 | 117 | 21
Southern Cuisine
1,600 | 1,653 | 53 | 28 | 1,231 | 8 | 172 | 20
1,200 | 1,225 | 50 | 31 | 867 | 9 | 142 | 21
Mexican-American Cuisine
1,600 | 1,638 | 56 | 27 | 1,616 | 9 | 143 | 20
1,200 | 1,239 | 58 | 26 | 1,364 | 8 | 91 | 19
Lacta-Ovo Vegetarian Cuisine
1,600 | 1,650 | 56 | 27 | 1,829 | 8 | 82 | 19
1,200 | 1,205 | 60 | 25 | 1,335 | 7 | 44 | 18

Table VI.A.4.a Sample Menu: Traditional American Cuisine, Reduced Calorie

| 1,600 Calories | | 1,200 Calories
Breakfast
Whole Wheat Bread | 1 slice | | 1 slice
Jelly, regular | 2 tsp | | 2 tsp
Cereal, Shredded Wheat | 1 cup | | ½ cup
Milk, 1% low-fat | 1 cup | | 1 cup
Orange Juice | ¾ cup | | ¾ cup
Coffee, Regular | 1 cup | | 1 cup
Milk, 1% low-fat | 1 oz | | —
Lunch
Roast Beef Sandwich
Whole Wheat Bread | 2 slices | | 2 slices
Lean Roast Beef, unseasoned | 2 oz | | 2 oz
American Cheese, low-fat, low-sodium | 1 slice (¾ oz) | | —
Lettuce | 1 leaf | | 1 leaf
Tomato | 3 slices | | 3 slices
Mayonnaise, low-calorie | 2 tsp | | 1 tsp
Apple | 1 medium | | 1 medium
Water | 1 cup | | 1 cup
Dinner
Salmon | 3 oz | | 2 oz
Vegetable Oil | 1 ½ tsp | | 1 ½ tsp
Baked Potato | ¾ medium | | ¾ medium
Margarine | 1 tsp | | 1 tsp
Carrots seasoned with | ½ cup | | ½ cup
margarine | ½ tsp | | —
Green Beans seasoned with | ½ cup | | ½ cup
margarine | ½ tsp | | ½ tsp
White Dinner Roll | 1 medium | | 1 small
Ice Milk | ½ cup | | —
Iced Tea, unsweetened | 1 cup | | 1 cup
Water | 2 cups | | 2 cups
Snack
Popcorn, air popped | 2½ cups | | 2½ cups
Margarine | 1½ tsp | | ¾ tsp
| Calories: | 1,613 | Calories: | 1,247
| Total Carb, % kcals: | 55 | Total Carb, % kcals: | 58
| Total Fat, % kcals: | 29 | Total Fat, % kcals: | 26
| *Sodium, mg: | 1,341 | *Sodium, mg: | 1,043
| SFA, % kcals: | 8 | SFA, % kcals: | 7
| Cholesterol, mg: | 142 | Cholesterol, mg: | 96
| Protein, % kcals: | 19 | Protein, % kcals: | 19

1,600: 100% RDA met for all nutrients except: Vit E 99%, Iron 73%, Zinc 91%

1,200: 100% RDA met for all nutrients except: Vit E 80%, Vit B_2_ 96%, Vit B_6_ 94%, Calcium 68%, Iron 63%, Zinc 73%

* No salt added in recipe preparation or as seasoning. Consume at least 32 oz. water.

Table VI.A.4.b Sample Menu: Asian-American Cuisine, Reduced Calorie

| 1,600 Calories | | 1,200 Calories
Breakfast
Banana | 1 small | | 1 small
Whole Wheat Bread | 2 slices | | 1 slice
Margarine | 1 tsp | | 1 tsp
Orange Juice | ¾ cup | | ¾ cup
Milk, 1% low-fat | ¾ cup | | ¾ cup
Lunch
Beef Noodle Soup, canned, low-sodium | ½ cup | | ½ cup
Chinese Noodle and Beef Salad
Beef Roast | 3 oz | | 2 oz
Peanut Oil | 1½ tsp | | 1 tsp
Soy Sauce, low-sodium | 1 tsp | | 1 tsp
Carrots | ½ cup | | ½ cup
Zucchini | ½ cup | | ½ cup
Onion | ¼ cup | | ¼ cup
Chinese Noodles, soft-type | ¼ cup | | ¼ cup
Apple | 1 medium | | 1 medium
Tea, unsweetened | 1 cup | | 1 cup
Dinner
Pork Stir-fry with Vegetables
Pork Cutlet | 2 oz | | 2 oz
Peanut Oil | 1 tsp | | 1 tsp
Soy Sauce, low-sodium | 1 tsp | | 1 tsp
Broccoli | ½ cup | | ½ cup
Carrots | 1 cup | | ½ cup
Mushrooms | ¼ cup | | ½ cup
Steamed White Rice | 1 cup | | ½ cup
Tea, unsweetened | 1 cup | | 1 cup
Snack
Almond Cookies | 2 cookies | | —
Milk, 1% low-fat | ¾ cup | | ¾ cup
| Calories: | 1,609 | Calories: | 1,220
| Total Carb, % kcals: | 56 | Total Carb, % kcals: | 55
| Total Fat, % kcals: | 27 | Total Fat, % kcals: | 27
| *Sodium, mg: | 1,296 | *Sodium, mg: | 1,043
| SFA, % kcals: | 8 | SFA, % kcals: | 8
| Cholesterol, mg: | 148 | Cholesterol, mg: | 117
| Protein, % kcals: | 20 | Protein, % kcals: | 21

1,600: 100% RDA met for all nutrients except: Zinc 95%, Iron 87%, Calcium 93%

1,200: 100% RDA met for all nutrients except: Vit E 75%, Calcium 84%, Magnesium 98%, Iron 66%, Zinc 77%

* No salt added in recipe preparation or as seasoning. Consume at least 32 oz. water.

Table VI.A.4.c Sample Menu: Southern Cuisine, Reduced Calorie

| 1,600 Calories | | 1,200 Calories
Breakfast
Oatmeal, prepared with 1% low-fat milk | ½ cup | | ½ cup
Milk, 1% low-fat | ½ cup | | ½ cup
English Muffin | 1 medium | | —
Cream Cheese, light, 18% fat | 1 T | | —
Orange Juice | ¾ cup | | ½ cup
Coffee | 1 cup | | 1 cup
Milk, 1% low-fat | 1 oz | | 1 oz
Lunch
Baked Chicken, without skin | 2 oz | | 2 oz
Vegetable Oil | 1 tsp | | ½ tsp
Salad
Lettuce | ½ cup | | ½ cup
Tomato | ½ cup | | ½ cup
Cucumber | ½ cup | | ½ cup
Oil and Vinegar Dressing | 2 tsp | | 1 tsp
White Rice, seasoned with | ½ cup | | ¼ cup
margarine, diet | ½ tsp | | ½ tsp
Baking Powder Biscuit, prepared with vegetable oil | 1 small | | ½ small
Margarine | 1 tsp | | 1 tsp
Water | 1 cup | | 1 cup
Dinner
Lean Roast Beef | 3 oz | | 2 oz
Onion | ¼ cup | | ¼ cup
Beef Gravy, water-based | 1 T | | 1 T
Turnip Greens, seasoned with | ½ cup | | ½ cup
margarine, diet | ½ tsp | | ½ tsp
Sweet Potato, baked | 1 small | | 1 small
Margarine, diet | ½ tsp | | ¼ tsp
Ground Cinnamon | 1 tsp | | 1 tsp
Brown Sugar | 1 tsp | | 1 tsp
Cornbread prepared with margarine, diet | ½ medium slice | | ½ medium slice
Honeydew Melon | ¼ medium | | ^1^/_8_ medium
Iced Tea, sweetened with sugar | 1 cup | | 1 cup
Snack
Saltine Crackers, unsalted tops | 4 crackers | | 4 crackers
Mozzarella Cheese, part-skim, low-sodium | 1 oz | | 1 oz
| Calories: | 1,653 | Calories: | 1,225
| Total Carb, % kcals: | 53 | Total Carb, % kcals: | 50
| Total Fat, % kcals: | 28 | Total Fat, % kcals: | 31
| *Sodium, mg: | 1,231 | *Sodium, mg: | 867
| SFA, % kcals: | 8 | SFA, % kcals: | 9
| Cholesterol, mg: | 172 | Cholesterol, mg: | 142
| Protein, % kcals: | 20 | Protein, % kcals: | 21

1,600: 100% RDA met for all nutrients except: Vit E 97%, Magnesium 98%, Iron 78%, Zinc 90%

1,200: 100% RDA met for all nutrients except: Vit E 82%, Vit B_1_ & B_2_ 95%, Vit B_3_ 99%, Vit B_6_ 88%, Magnesium 83%, Iron 56%, Zinc 70%

* No salt added in recipe preparation or as seasoning. Consume at least 32 oz. water.

Table VI.A.4.d Sample Menu: Mexican-American Cuisine, Reduced Calorie

| 1,600 Calories | | 1,200 Calories
Breakfast
Cantaloupe | 1 cup | | ½ cup
Farina, prepared with 1% low-fat milk | ½ cup | | ½ cup
White Bread | 1 slice | | 1 slice
Margarine | 1 tsp | | 1 tsp
Jelly | 1 tsp | | 1 tsp
Orange Juice | 1½ cup | | ¾ cup
Milk, 1% low-fat | ½ cup | | ½ cup
Lunch
Beef Enchilada
Tortilla, corn | 2 tortillas | | 2 tortillas
Lean Roast Beef | 2 ½ oz | | 2 oz
Vegetable Oil | ^2^/_3_ tsp | | ^2^/_3_ tsp
Onion | 1 T | | 1 T
Tomato | 4 T | | 4 T
Lettuce | ½ cup | | ½ cup
Chili Peppers | 2 tsp | | 2 tsp
Refried Beans, prepared with vegetable oil | ¼ cup | | ¼ cup
Carrots | 5 sticks | | 5 sticks
Celery | 6 sticks | | 6 sticks
Milk, 1% low-fat | ½ cup | | —
Dinner
Chicken Taco
Tortilla, corn | 1 tortilla | | 1 tortilla
Chicken Breast, without skin | 2 oz | | 1 oz
Vegetable Oil | ^2^/_3_ tsp | | ^2^/_3_ tsp
Cheddar Cheese, low-fat, low-sodium | 1 oz | | ½ oz
Guacamole | 2 T | | 1 T
Salsa | 1 T | | 1 T
Corn, seasoned with | ½ cup | | ½ cup
margarine | ½ tsp | | —
Spanish Rice without meat, seasoned without margarine | ½ cup | | ½ cup
Banana | 1 large | | ½ large
Coffee | 1 cup | | 1 cup
Milk 1% | 1 oz | | 1oz
| Calories: | 1,638 | Calories: | 1,239
| Total Carb, % kcals: | 56 | Total Carb, % kcals: | 58
| Total Fat, % kcals: | 27 | Total Fat, % kcals: | 26
| *Sodium, mg: | 1,616 | *Sodium, mg: | 1,364
| SFA, % kcals: | 9 | SFA, % kcals: | 8
| Cholesterol, mg: | 143 | Cholesterol, mg: | 91
| Protein, % kcals: | 20 | Protein, % kcals: | 19

1,600: 100% RDA met for all nutrients except: Vit E 97%, Zinc 84%

1,200: 100% RDA met for all nutrients except: Vit E 71%, Vit B_1_ & B_3_ 91%, Vit B_2_ & Iron 90%,Calcium 92%, Magnesium 95%, Zinc 64%

* No salt added in recipe preparation or as seasoning. Consume at least 32 oz. water.

Table VI.A.4.e Sample Menu: Lacto-Ovo Vegetarian Cuisine, Reduced Calorie

| 1,600 Calories | | 1,200 Calories
Breakfast
Orange | 1 medium | | 1 medium
Pancakes, made with 1% low-fat milk, egg whites | 3 4" circles | | 2 4" circles
Pancake Syrup | 2 T | | 1 T
Margarine, diet | 1½ tsp | | 1½ tsp
Milk, 1% low-fat | 1 cup | | ½ cup
Coffee | 1 cup | | 1 cup
Milk, 1% low-fat | 1 oz | | 1 oz
Lunch
Vegetable Soup, canned, low-sodium | 1 cup | | ½ cup
Bagel | 1 medium | | ½ medium
Processed American Cheese, low-fat and low sodium | ¾ oz | | —
Spinach Salad
Spinach | 1 cup | | 1 cup
Mushrooms | ^1^/_8_ cup | | ^1^/_8_ cup
Salad Dressing, regular calorie | 2 tsp | | 2 tsp
Apple | 1 medium | | 1 medium
Iced Tea, unsweetened | 1 cup | | 1 cup
Dinner
Omelette
Egg Whites | 4 large eggs | | 4 large eggs
Green Pepper | 2 T | | 2 T
Onion | 2 T | | 2T
Mozzarella Cheese, made from part-skim milk, low-sodium | 1½ oz | | 1 oz
Vegetable Oil | 1 T | | ½ T
Brown Rice, seasoned with | ½ cup | | ½ cup
margarine, diet | ½ tsp | | ½ tsp
Carrots, seasoned with | ½ cup | | ½ cup
margarine, diet | ½ tsp | | ½ tsp
Whole Wheat Bread | 1 slice | | 1 slice
Margarine, diet | 1 tsp | | 1 tsp
Fig Bar Cookie | 1 bar | | 1 bar
Tea | 1 cup | | 1 cup
Honey | 1 tsp | | 1 tsp
Snack
Milk, 1% low-fat | ¾ cup | | ¾ cup
| Calories: | 1,650 | Calories: | 1,205
| Total Carb, % kcals: | 56 | Total Carb, % kcals: | 60
| Total Fat, % kcals: | 27 | Total Fat, % kcals: | 25
| *Sodium, mg: | 1,829 | *Sodium, mg: | 1,335
| SFA, % kcals: | 8 | SFA, % kcals: | 7
| Cholesterol, mg: | 82 | Cholesterol, mg: | 44
| Protein, % kcals: | 19 | Protein, % kcals: | 18

1,600: 100% RDA met for all nutrients except: Vit E 92%, Vit B_3_ 97%, Vit B_6_ 67%, Magnesium 98%, Iron 73%, Zinc 68%

1,200: 100% RDA met for all nutrients except: Vit E 75%, Vit B_1_ 92%, Vit B_3_ 69%, Vit B_6_ 59%, Iron 54%, Zinc 46%

* No salt added in recipe preparation or as seasoning. Consume at least 32 oz. water.